# Acknowledgments

The National Center for Health Statistics’ (NCHS) Office of Analysis and Epidemiology planned and coordinated the content of this volume under the direction of Renee M. Gindi, Julia S. Holmes, and Irma E. Arispe.

Production of Health, United States, 2017 was coordinated by Sheila J. Franco, Hashini S. Khajuria, Florence C. Lee, and Ashley M. Woodall. Preparation of the volume, including highlights, trend tables, appendixes, and index, was completed by Shilpa Bengeri, Mary Ann Bush, La-Tonya D. Curl, Barnali Das, Catherine R. Duran, Sheila J. Franco, Mary Anne Freedman, Suzanne Hallquist, Nancy Han, Hashini S. Khajuria, Ji-Eun Kim, Florence C. Lee, Xianfen Li, Diane M. Makuc, Zakia C. Nelson, Anita L. Powell, and Ashley M. Woodall. Administrative and word processing assistance was provided by Lillie C. Featherstone.

Production of the Chartbook was managed by Sheila J. Franco. Data, analysis, and text for specific charts were provided by Shilpa Bengeri, Mary Ann Bush, La-Tonya D. Curl, Catherine R. Duran, Sheila J. Franco, Suzanne Hallquist, Nancy Han, Hashini S. Khajuria, Ji-Eun Kim, Florence C. Lee, Xianfen Li, Diane M. Makuc, Zakia C. Nelson, Anita L. Powell, and Ashley M. Woodall.

Publication assistance was provided by CDC/OSELS/NCHS/OD/Office of Information Services, Information Design and Publishing Staff (IDPS). Editing was provided by Danielle Taylor and graphic design was provided by Kyung M. Park. Cover design was provided by Sarah Hinkle. Printing was managed by Nathanael Brown (CDC/OD/OADC). Publication production was performed under contract with Tanaq Government Services, LLC. Electronic access through the NCHS website was provided by Shilpa Bengeri, La-Tonya D. Curl, Brandon DiMichele (contractor), Mary Anne Freedman, Hashini S. Khajuria, Florence C. Lee, Diane M. Makuc, Jennifer A. Moore, and Ashley M. Woodall.

Data and technical assistance were provided by staff of the following NCHS organizations: Division of Health Care Statistics: Jill Ashman, Pinyao Rui, Susan M. Schappert, Manisha Sengupta, Victor V. Shigaev, and Iris M. Shimizu; Division of Health and Nutrition Examination Surveys: Lara Akinbami, Margaret D. Carroll, Mark S. Eberhardt, Cheryl Fryar, Tatiana Nwankwo, Cynthia L. Ogden, Yechiam Ostchega, Ryne Paulose-Ram, and Chia-Yih Wang; Division of Health Interview Statistics: Veronica Benson, Lindsey Black, Debra Blackwell, Tainya Clarke, Robin A. Cohen, Jacqueline Lucas, Tina Norris, Jeannine Schiller, Charlotte Schoenborn, Anjel Vahratian, Maria Villarroel, and Emily P. Zammitti; Division of Vital Statistics: Robert N. Anderson, Joyce A. Arbertha, Elizabeth Arias, Anjani Chandra, Kimberly Daniels, Anne K. Driscoll, Danielle Ely, Elizabeth Gregory, Brady Hamilton, Donna L. Hoyert, Joyce A. Martin, T.J. Mathews, Arialdi M. Miniño, Steven J. Steimel, Betzaida Tejada-Vera, and Margaret Warner; Office of Analysis and Epidemiology: Lesley J. Dobrzynski, Nazik Elgaddal, Cordell Golden, Deborah D. Ingram, Sibeso Joyner, Deepthi Kandi, Lisa Mirel, Jeff Pearcy, Cheryl V. Rose, Makram Talih, and Julie Weeks; Office of the Center Director: Juan Albertorio and Francis C. Notzon; and Division of Research and Methodology: Donald J. Malec.

Additional data and technical assistance were provided by the following organizations of the Centers for Disease Control and Prevention (CDC): National Center for Chronic Disease Prevention and Health Promotion: Maegan Boutot, Andrea Gentzke, David M. Homa, Sean Hu, Ahmed Jamal, and Tara Jatlaoui; National Center for HIV/AIDS, Viral Hepatitis, STD, and TB Prevention: Lori Elmore, Anna Satcher Johnson, Jennifer Ludovic, Elizabeth Torrone, and the Surveillance and Data Management Branch; National Center for Immunization and Respiratory Diseases: Laurie D. Elam-Evans, Holly A. Hill, Samuel F. Posner, and Tanja Y. Walker; OPHSS/CSELS, Division of Health Informatics and Surveillance: Ruth Ann Jajosky, Tara Strine, and Kimberly Thomas; by the following organizations within the Department of Health and Human Services: Agency for Healthcare Research and Quality: Anne Elixhauser and Pradip K. Muhuri; Centers for Medicare & Medicaid Services: Mary Carol Barron, Stephanie Bartee, Aaron Catlin, Tony Dean, Maria Diacogiannis, Nathan Espinosa, Micah Hartman, Deborah Kidd, Barbara S. Klees, Maggie S. Murgolo, Debra Reed-Gillette, Joseph F. Regan, Jeffrey S. Silverman, and Lekha S. Whittle; Health Resources & Services Administration: Shafali Srivastave; National Institutes of Health: Nadia Howlander and Marsha Lopez; Substance Abuse and Mental Health Services Administration: Beth Han and Neil Russell; and by the following governmental and nongovernmental organizations: U.S. Census Bureau: Bernadette Proctor and Danielle Taylor; Bureau of Labor Statistics: Elizabeth A. Ashack, Matt Gunter, Jesus Ranon, and Audrey Watson; Department of Veterans Affairs: Tom Garin; American Association of Colleges of Pharmacy: Nancy T. Nguyen, Danielle A. Taylor, and Jamie N. Taylor; American Association of Colleges of Osteopathic Medicine: Lindsey Jurd; American Association of Colleges of Podiatric Medicine: Moraith G. North; American Dental Association: Bradley Munson; Association of American Medical Colleges: Brianna Gunter; Association of Schools and Colleges of Optometry: Joanne C. Zuckerman; Association of Schools & Programs of Public Health: Christine M. Plepys; University of Michigan, Monitoring the Future: Adam Burke and Richard Miech; Information Management Services, Inc.: Marty Krapcho; and Cowles Research Group: C. McKeen Cowles.

We acknowledge the contributions from local, state, and territorial health departments and other sources in the collection and reporting of health indicators.