# Highlights

This Highlights section includes this year’s Special Feature on Mortality, as well as data from the four subject areas of Health, United States—health status and determinants, utilization of health resources, health care resources, and health care expenditures and payers. The Highlights section generally presents trends for the recent 10-year period or examines information for the most recent data year for topics of public health interest. Each highlight includes a reference to the detailed trend table or figure where definitions of terms and additional data can be obtained, available from the Health, United States, 2017 website: https://www.cdc.gov/nchs/hus/contents2017.htm.

## Special Feature on Mortality

Between 2006 and 2016, life expectancy at birth in the U.S. for the total population increased 0.8 years—from 77.8 years to 78.6 years. Despite an overall increase over this 10-year period, life expectancy at birth decreased in recent years for the first time since 1993. Between 2014 and 2015, life expectancy at birth decreased 0.2 years. Between 2015 and 2016, life expectancy at birth decreased another 0.1 years (Table 15 and Figure 20).

In 2016, life expectancy at birth was 76.1 years for males and 81.1 years for females—a difference of 5.0 years (Table 15 and Figure 20).

Between 2006 and 2016, life expectancy at birth increased more for the non-Hispanic black population than for the non-Hispanic white population, thereby narrowing the gap in life expectancy between these two racial groups. In 2006, life expectancy at birth for the non-Hispanic white population was 5.1 years longer than for the non-Hispanic black population; by 2016, the difference had narrowed to 3.7 years (Table 15 and Figure 1).

In 2016, life expectancy at birth was highest for Hispanic persons at 81.8 years, compared to 78.5 years for non-Hispanic white persons and 74.8 years for non-Hispanic black persons (Table 15).

In 2016, the top 10 leading causes of death were heart disease, cancer, unintentional injuries, chronic lower respiratory diseases, stroke, Alzheimer’s disease, diabetes, influenza and pneumonia, kidney disease, and suicide (Table 19 and Figure 2).

Between 2006 and 2016, the age-adjusted death rate decreased 8%, from 791.8 to 728.8 deaths per 100,000 resident population (Table 17).

Between 2005 and 2015, the infant mortality rate decreased 14%, from 6.86 to 5.90 deaths per 1,000 live births; however, differences by race and ethnicity remained. In 2015, the infant mortality rate was 2.8 times as high among infants of non-Hispanic black mothers (11.25 deaths per 1,000 live births) as among infants of non-Hispanic Asian or Pacific Islander mothers (4.08 deaths per 1,000 live births) (Figure 22).

The death rate for unintentional injury among children aged 1–14 years—the leading cause of death for this age group—decreased an average of 6.8% per year from 2006–2010 and remained stable from 2010–2016. The death rates for other leading causes of death in 2016—cancer, congenital malformations, homicide, and heart disease—declined during 2006–2016, while the suicide rate doubled (Figure 23).

Among persons aged 15–24 years, the leading causes of death in 2016 were unintentional injury, suicide, homicide, cancer, heart disease, and congenital malformations. Death rates for unintentional injuries and homicide declined during 2006–2013 and 2006–2014, respectively; homicide rates increased, while unintentional injury death rates were stable through 2016. Suicide rates increased during 2006–2016. Death rates for the remaining leading causes of death declined during 2006–2016 (Table 20 and Figure 23).

Unintentional injury, cancer, suicide, heart disease, homicide, and chronic liver disease were the leading causes of death for persons aged 25–44 in 2016. During 2006–2016, the suicide rate increased by an average of 1.7% per year. Chronic liver disease death rates increased by an average of 5.3% per year during 2012–2016 after an initial period of no change. The homicide and unintentional injuries death rates also increased sharply at the end of the period (Table 20 and Figure 24).

Cancer and heart disease were the top two causes of death among persons aged 45–64 in 2016, followed by unintentional injuries, chronic lower respiratory disease (CLRD), chronic liver disease and cirrhosis, diabetes, and stroke. Between 2006 and 2016, the death rates for unintentional injuries, CLRD, chronic liver disease and cirrhosis, and diabetes increased, while death rates for cancer, heart disease, and stroke declined (Table 20 and Figure 24).

Heart disease and cancer were the top two causes of death among persons aged 65 and over in 2016. During 2006–2016, the death rate for heart disease decreased by an average of 3.5% per year during 2006–2012, and then by an average of 1.6% per year during 2012–2016. The death rate for cancer decreased by an average 1.6% per year during 2006–2010, and then by an average of 2.2% per year during 2010–2016 (Table 20 and Figure 25).

The death rate for stroke—the fourth leading cause of death among adults aged 65 and over in 2016—decreased from 314.8 in 2006 to 247.0 in 2016 (Figure 25).

The death rate for Alzheimer’s disease—the fifth leading cause of death among persons aged 65 and over in 2016—remained stable from 2006–2013, and then increased by an average of 6.9% per year during 2013–2016, from 187.4 to 233.3 deaths per 100,000; the risk of dying from Alzheimer’s disease increased significantly with age (Figure 25).

During 2006–2016, heart disease and cancer (malignant neoplasms) were the top two causes of death. The age-adjusted heart disease death rate declined 19%, from 205.5 to 165.5 deaths per 100,000 resident population, over this period. The age-adjusted cancer death rate declined 14%, from 181.8 to 155.8 deaths per 100,000 resident population (Table 17).

In 2016, there were 63,632 deaths from drug overdoses—two-thirds (66.4%) of which involved an opioid. Between 2006 and 2016, the age-adjusted death rate for drug overdose increased from 11.5 to 19.8 deaths per 100,000 (Table 27 and Figure 26).

Drug overdose death rates were higher among males than females, and the trend varied by sex and age. The recent increases in drug overdose death rates were especially pronounced among men aged 25–34 and women aged 15–24—for whom drug overdose death rates increased by an average of 26.7% per year and 19.4% per year, respectively, during 2014–2016 (Figure 26).

In 2016, age-adjusted drug overdose death rates varied by state, ranging from a low of 6.4 deaths per 100,000 population in Nebraska to a high of 52.0 deaths per 100,000 in West Virginia (Figure 27).

Between 2006 and 2016, the age-adjusted suicide death rate increased 23%, from 11.0 to 13.5 deaths per 100,000 resident population. In 2016, suicide rates differed by sex and age. Men aged 75 and over had the highest suicide rate among males (39.2 deaths per 100,000), while women aged 45–64 had the highest suicide rate among females (9.9 deaths per 100,000) (Table 30 and Figure 28).

During 2006–2016, death rates for chronic liver disease and cirrhosis were higher among men than among women. In 2016, among men, those aged 55–64 had the highest chronic liver disease and cirrhosis death rate (45.9 deaths per 100,000), while among women, those aged 75 and over had the highest death rate (23.8 deaths per 100,000) (Figure 29).

## Health Status and Determinants

### Fertility and Natality

Between 2006 and 2016, the birth rate among teenagers aged 15–19 years fell nearly 50%, from 41.1 to 20.3 live births per 1,000 females—a record low for the U.S. (Table 3).

In 2016, 8.17% of infants were low birthweight (weighing less than 2,500 grams [5.5 pounds] at birth). Low birthweight was more common among infants of non-Hispanic black mothers (13.53%) and infants of Puerto Rican mothers (9.50%) than among infants of mothers in other racial and ethnic groups (Table 5).

In 2016, the percentage of live singleton births that were born preterm (less than 37 weeks gestation) ranged from 7.1% among non-Hispanic white mothers to 11.5% among non-Hispanic black mothers. The percentage of live singleton births born at less than 32 weeks ranged from 0.9% among non-Hispanic white and non-Hispanic Asian or Pacific Islander mothers to 2.6% among non-Hispanic black mothers (Figure 4).

### Health Risk Factors for the Noninstitutionalized Population

#### Children

In 2013–2016, the prevalence of obesity among boys aged 2–19 years ranged from 11.9% for non-Hispanic Asian or Pacific Islander boys to 24.3% among Hispanic boys. Among girls aged 2–19 years, the prevalence of obesity ranged from 7.4% among non-Hispanic Asian or Pacific Islander girls to 22.9% among Hispanic girls and 23.0% among non-Hispanic black girls (Figure 7).

Between 2011 and 2016, the percentage of high school students who smoked cigarettes in the past 30 days declined from 15.8% to 8.0%, while use of electronic cigarettes increased more than seven-fold, from 1.5% to 11.3% (Figure 5).

#### Adults

In 2016, 21.9% of adults aged 18 and over met the 2008 federal physical activity guidelines for both aerobic activity and muscle strengthening (Table 57).

In 2013–2016, the prevalence of overweight among adults aged 20 years was 71.1%, including 38.9% with obesity (Table 58).

In 2016, 15.7% of adults aged 18 and over were current cigarette smokers, a decline from 20.8% in 2006 (age-adjusted percentages). In 2016, 16.4% of adults aged 18–44, 18.0% of adults 45–64, and 8.8% of adults 65 and over were current smokers (Table 47 and Figure 5).

### Measures of Health and Disease Prevalence for the Noninstitutionalized Population

The prevalence of current asthma in children under age 18 years declined from 9.3% in 2006 to 8.3% in 2016. The prevalence of current asthma in non-Hispanic black children was higher than for Hispanic and non-Hispanic white children during the entire 2006–2016 period (Figure 8).

Between 1997–1999 and 2014–2016, the percentage of children and adolescents aged 5–17 years diagnosed with attention-deficit/hyperactivity disorder (ADHD) increased from 6.5% to 10.6% (Table 35).

Between 2006 and 2016, the incidence rates of tuberculosis, hepatitis A, hepatitis B, and meningococcal disease decreased, while the incidence rates of hepatitis C nearly quadrupled, from 0.26 to 0.97 new cases per 100,000 population, and the incidence rates for all stages of syphilis more than doubled, from 12.34 to 27.25 new cases per 100,000 population. Despite overall decline in acute hepatitis A cases between 2006 and 2016, there was a 44% increase in the number of new cases between 2015 and 2016 (Table 33).

In 2016, the percentage of adults who reported their health as fair or poor ranged from 3.9% of those aged 18–24 to 25.7% of those aged 75 and over (Table 45).

In 2016, the percentage of adults reporting functional limitation at the “A lot of difficulty or cannot do at all” level was higher among adults aged 65 and over (18.2%) than among adults 18–64 (6.2%) (Table 42).

During 1999–2000 through 2015–2016, the prevalence of hypertension (systolic pressure of at least 140 mm Hg or diastolic pressure of at least 90 mm Hg and/or taking antihypertensive medication) among persons aged 20–44 was generally higher for men than women, while among persons aged 65 and over, the prevalence of hypertension was generally higher for women than men (Figure 10).

In 2015–2016, men aged 20–44 (32.5%) were nearly two times as likely as women aged 20–44 to be unaware of their hypertension (17.0%) (Figure 10).

During 2006–2016, the prevalence of heart disease increased with age. In 2016, the prevalence of heart disease was higher among men than women for age groups 55–64 and 65 and over, and was not statistically different for adults aged 45–54 (Figure 9).

The prevalence of diabetes increased with age; in 2011–2014, the prevalence of diabetes was 4.0% among adults aged 20–44, 16.6% among adults aged 45–64, and 26.3% among adults aged 65 and over (Table 40).

## Utilization of Health Resources for the Noninstitutionalized Population

### Use of Health Care Services

In 2016, 14.1% of persons had no health care visits in the past 12 months, 48.9% had 1–3 health care visits, 23.8% had 4–9 visits, and 13.3% had 10 or more visits (Table 65).

In 2015, there were 991 million visits to physician offices and 137 million visits to hospital emergency departments, compared to 1,009 million and 130 million visits, respectively, in 2010 (Table 76).

During 2006–2016, adults aged 65 years and over were generally more likely than younger age groups to have had an emergency department (ED) visit in the past 12 months. In 2016, women (21.7%, age-adjusted) were more likely than men (17.0%, age-adjusted) to have had one or more visits to the ED in the past 12 months (Table 74 and Figure 13).

In 2016, 84.6% of children aged 2–17 years, 64.4% of adults aged 18–64, and 64.3% of adults aged 65 and over had visited a dentist in the past year (Table 78).

### Use of Preventive Medical Care Services for the Noninstitutionalized Population

In 2016, 70.7% of children aged 19–35 months had completed the combined 7-vaccine series of childhood vaccinations (includes diphtheria, tetanus, pertussis, poliovirus, and measles, among others). In 2016, combined 7-vaccine series coverage among children aged 19–35 months varied by state, ranging from 58.1% in Oregon to 85.3% in Massachusetts (Table 66 and Figure 12).

Between 2008 and 2016, receipt of the full series of human papillomavirus (HPV) vaccine for adolescents aged 13–17 years increased among females from 17.9% to 43.0%. Receipt of the full series for males aged 13–17 years increased from 1.3% in 2011 to 31.5% in 2016 (Table 67).

Between 2006 and 2016, the percentage of adults aged 18 and over who had received an influenza vaccination in the past 12 months increased from 27.6% to 42.2%. In 2016, influenza vaccination increased with age, ranging from 31.1% of adults aged 18–44, to 67.5% of adults aged 65 and over (Table 68).

In 2016, 66.9% of adults aged 65 and over had ever received a pneumococcal vaccination, up from 57.1% in 2006 (Table 69).

### Difficulty Accessing Needed Medical Care Due to Cost for the Noninstitutionalized Population

The percentage of adults aged 18–64 who reported delaying or not receiving needed medical care due to cost decreased from 11.7% in 2006 to 9.8% in 2016 (Table 63).

In 2016, adults aged 18–64 with family incomes below 100% or at 100%–199% of the poverty level were more than three times as likely as those at 400% or more of the poverty level to delay or not receive needed medical care due to cost (Table 63 and Figure 14).

In 2015–2016, children under age 18 years without health insurance were more likely to lack a usual source of care (27.9%) than children who had private coverage (2.6%) or Medicaid (4.6%) (Table 61).

## Health Care Resources

In 2015, 58.8% of physician visits were to specialist physicians and 41.2% were to primary care physicians (Table 77).

In 2015, the U.S. had 4,862 community hospitals and 782,188 community hospital beds. Community hospital occupancy averaged 63.6% in 2015, down from 67.3% in 2005 (Table 89).

Between 2010 and 2015, the number of professionally active physicians increased from 27.2 to 29.2 physicians per 10,000 civilian population. In 2015, the number of active physicians per 10,000 population ranged from 19.6 in Mississippi to 74.6 in the District of Columbia (Table 83).

Between 2006 and 2016, the number of professionally active dentists increased from 57.85 to 60.79 dentists per 100,000 civilian population. In 2016, the number of dentists per 100,000 population ranged from 41.16 in Arkansas to 88.52 in the District of Columbia (Table 86).

Between 2006 and 2016, the U.S. nursing home occupancy rate decreased from 83.5% to 79.7%. In 2016, nursing home occupancy rates were highest—at approximately 90%—in South Dakota, North Dakota, the District of Columbia, and New York. The lowest occupancy rates in 2016 were in Utah (64.2%) and Indiana (63.1%) (Table 92).

## Health Care Expenditures and Payers

### Health Care Expenditures

In 2016, personal health care expenditures in the U.S. totaled $2.8 trillion—a 4.4% increase from 2015. The per capita personal health care expenditures for the total U.S. population was $8,788 in 2016—up 3.6% from $8,479 in 2015 (Table 93).

In 2016, expenditures for hospital care accounted for 38.2%, physician and clinical services accounted for 23.5%, and prescription drugs accounted for 11.6% of personal health care expenditures, amounting to nearly three-quarters of total personal health care expenditures. The remaining expenditures included nursing care facilities and continuing care retirement communities (5.7%), dental (4.4%), home health care (3.3%), and other professional services (3.2%) (Table 94 and Figure 17).

In 2016, prescription drug expenditures totaled $328.6 billion—up 1.3% from $324.5 billion in 2015 (Table 94).

### Health Care Payers

In 2016, 35.1% of all personal health care expenditures were paid by private health insurance, 22.1% were paid by Medicare, and 17.8% by Medicaid; consumers paid 12.4% out-of-pocket; and the remaining expenditures were paid by other types of insurance, payers, and programs (Table 95).

In 2016, the Medicare program had 56.8 million enrollees and expenditures totaling $678.7 billion (preliminary estimates)—up from 55.5 million enrollees and $647.6 billion in expenditures from the previous year. Expenditures for the Medicare drug program (Part D) were $100.0 billion in 2016 (preliminary estimates)—up from $89.8 billion in 2015 (Table 107).

Between 2006 and 2016, the percentage of Medicare enrollees in managed care increased from 16.9% to 32.5%. In 2016, the percentage of Medicare enrollees in managed care varied by state from 1.0% in Alaska to 55.6% in Minnesota (Table 112).

### Health Insurance Coverage for the Noninstitutionalized Population

Between 2006 and 2017 (preliminary estimates), the percentage of children under age 18 years with Medicaid coverage increased from 28.8% to 36.3%, and the percentage of children who were uninsured decreased from 9.5% to 5.0% (Figure 18).

Between 2006 and 2017 (preliminary estimates), the percentage of adults aged 18–64 with Medicaid coverage increased from 7.4% to 13.1%, and the percentage of adults who were uninsured decreased from 20.0% to 12.8% (Figure 19).

In 2016, Massachusetts (3.5%) had the lowest and Texas (22.7%) had the highest percentage of persons uninsured (i.e., without public or private coverage) among those aged 18–64. Among children under age 18 years, Massachusetts (0.9%) had the lowest and Alaska (10.7%) had the highest percentage uninsured (Table 114).