# Appendix II Definitions and Methods

This appendix contains an alphabetical listing of terms used in Health, United States, and these definitions are specific to the data presented in this report The methods used for calculating age-adjusted rates, average annual rates of change, relative standard errors, birth rates, death rates, and years of potential life lost are described. Included are standard populations used for age adjustment (Tables I and II), the years when the revisions for International Classification of Diseases (ICD) codes were in effect (Table III), codes for cause of death from the 6th through 10th revisions of ICD (Table IV), comparability ratios between the 9th and 10th revisions (ICD-9 and ICD-10) for selected causes (Table V), a comparison of high blood pressure based on two standards for high blood pressure (Table VI), imputed family income percentages from the National Health Interview Survey (NHIS) (Table VII), an analysis of the effect of added probe questions for Medicare and Medicaid coverage on health insurance rates in NHIS (Table VIII), industry codes from the North American Industry Classification System (Table IX), and ICD-9 Clinical Modification (ICD-9-CM) codes for external causes of injury and procedure categories (Tables X and XI). Standards for presenting federal data on race and ethnicity are described, and sample tabulations of NHIS data comparing the 1977 and 1997 Office of Management and Budget standards for the classification of federal data on race and ethnicity are presented in Tables XII and XIII.

## Acquired immunodeficiency syndrome (AIDS)

Human immunodeficiency virus (HIV) is the pathogen that causes AIDS, and HIV disease is the term that encompasses all of the condition’s stages—from infection to the deterioration of the immune system and the onset of opportunistic diseases. However, AIDS is still a term commonly used to refer to the immune deficiency caused by HIV. If a person with HIV is diagnosed with at least one of a set of opportunistic illnesses or has laboratory values indicating advanced disease, he or she may be diagnosed as having AIDS. All 50 states, the District of Columbia, and 6 U.S. dependent areas (American Samoa, Guam, Northern Mariana Islands, Puerto Rico, Republic of Palau, and U.S. Virgin Islands) report confirmed diagnoses of HIV infection and AIDS cases to the Centers for Disease Control and Prevention using a uniform surveillance case definition and case report form. The case reporting definitions have changed over time to incorporate a broader range of AIDS-indicator diseases and conditions and use HIV diagnostic tests to improve the sensitivity and specificity of the definition. Because of these case definition changes, caution should be used when interpreting AIDS trends. (Also see Appendix II, Human immunodeficiency virus [HIV] disease.)

## Active physician

See Appendix II, Physician.

## Activities of daily living (ADL)

Activities related to personal care, including bathing or showering, dressing, getting into or out of bed or a chair, using the toilet, and eating. (Also see Appendix II, Functional limitation; Instrumental activities of daily living [IADL]; Limitation of activity.)

Medicare Current Beneficiary Survey—The following personal care activities are defined as ADLs: bathing or showering, dressing, getting into or out of bed or a chair, using the toilet, and eating. If sample persons had any difficulty performing an activity by themselves and without special equipment, or did not perform the activity at all because of health problems, they were categorized as having a limitation in that activity. The limitation may have been temporary or chronic at the time of interview. Sampled persons who were administered a community interview answered questions about health status and functioning themselves, if able to do so. If the sample persons were not able to respond, a proxy answered the questions. For persons in a long-term care facility, a proxy, such as a nurse, answered questions about their health status and functioning. Starting in 1997, interview questions for people residing in long-term care facilities were changed slightly from those administered to people living in the community in order to differentiate residents who were independent from those who received supervision or assistance with transferring, locomotion on unit, dressing, eating, toileting, and bathing.

National Health Interview Survey (NHIS)—Respondents were asked whether they or family members need the help of another person with personal care activities, such as eating, bathing, dressing, or getting around inside the home because of a physical, mental, or emotional problem.

## Admission

The American Hospital Association defines admissions as persons, excluding newborns, accepted for inpatient services during the survey reporting period. (Also see Appendix II, Days of care; Discharge; Inpatient.)

## Age

Reported as age at last birthday (i.e., age in completed years), often calculated by subtracting an individual’s date of birth from the reference date, with the reference date being the date of the examination, interview, or other contact.

Mother’s (maternal) age is reported on the birth certificate by all states. Birth statistics are presented for mothers aged 10-49 through 1996 and aged 10-54 starting in 1997, based on mother’s date of birth or age as reported on the birth certificate. The age of the mother is edited for upper and lower limits. When the age of the mother is computed to be under 10 or 55 and over (50 and over in 1964-1996), it is considered not stated and is imputed according to the age of the mother from the previous birth record of the same race and total birth order (total of fetal deaths and live births). Before 1963, not-stated ages were distributed in proportion to the known ages for each racial group.

Table I United States projected year 2000 standard population and age groups used to age-adjust data

Data system and age | Population
DVS mortality data
Total | 274,633,642
Under 75 years | 258,059,676
Under 1 year | 3,794,901
1–4 years | 15,191,619
5–14 years | 39,976,619
15–24 years | 38,076,743
25–34 years | 37,233,437
35–44 years | 44,659,185
45–54 years | 37,030,152
55–64 years | 23,961,506
65–74 years | 18,135,514
75–84 years | 12,314,793
85 years and over | 4,259,173
DVS (Table 18)
Under 75 years | 258,059,676
Under 1 year | 3,794,901
1–14 years | 55,168,238
15–24 years | 38,076,743
25–34 years | 37,233,437
35–44 years | 44,659,185
45–54 years | 37,030,152
55–64 years | 23,961,506
65–74 years | 18,135,514
NHIS, NAMCS, and NHAMCS
All ages | 274,633,642
18 years and over | 203,852,188
25 years and over | 177,593,760
40 years and over | 118,180,367
65 years and over | 34,709,480
Under 18 years | 70,781,454
2–17 years | 63,227,991
18–44 years | 108,151,050
18–24 years | 26,258,428
25–34 years | 37,233,437
35–44 years | 44,659,185
45–64 years | 60,991,658
45–54 years | 37,030,152
55–64 years | 23,961,506
65–74 years | 18,135,514
75 years and over | 16,573,966
18–49 years | 127,956,843
40–64 years:
40–49 years | 42,285,022
50–64 years | 41,185,865
NHANES
20 years and over | 195,850,985
20–34 years | 55,490,662
35–44 years | 44,659,185
45–54 years | 37,030,152
55–64 years | 23,961,506
65 years and over | 34,709,480
NHANES (Tables 40 and 53)
20–44 years | 100,149,847
45–64 years | 60,991,658
65 years and over | 34,709,480
NHANES (Table 56)
20–44 years | 100,149,847
45–64 years | 60,991,658
65–74 years | 18,135,514
75 years and over | 16,573,966
NHANES (Table 79)
Under 18 years | 70,781,454
18–44 years | 108,151,050
45–64 years | 60,991,658
65 years and over | 34,709,480

NOTES: DVS is Division of Vital Statistics. NHIS is National Health Interview Survey. NAMCS is National Ambulatory Medical Care Survey. NHAMCS is National Hospital Ambulatory Medical Care Survey. NHANES is National Health and Nutrition Examination Survey. Tables listed by data system indicate use of populations in this report.

SOURCE: National Institutes of Health, National Cancer Institute, Surveillance, Epidemiology, and End Results (SEER). Standard populations—single ages. Available from: https://seer.cancer.gov/stdpopulations/.

Beginning in 1997, the birth rate for the maternal age group 45-49 has included data for mothers aged 50-54 in the numerator and has been based on the population of women aged 45-49 in the denominator Beginning with 2003 data, age of mother is imputed for stated ages 8 and under and 65 and over, for births reported using the 2003 revision of the birth certificate. Starting with 2007 data, age of mother is imputed for all births for stated ages 8 and under and 65 and over, regardless of the birth certificate version used. As with data for earlier years, age is imputed according to the age of mother from the previous record with the same race and total birth order.

## Age adjustment

Used to compare risks for two or more populations at one point in time or for one population at two or more points in time Age-adjusted rates are computed using the direct method by applying age-specific rates in a population of interest to a standardized age distribution, to eliminate differences in observed rates that result from age differences in population composition. Age-adjusted rates should be viewed as relative indexes rather than actual measures of risk.

Table II United States projected year 2000 standard population and proportion distribution by age, for age-adjusting death rates prior to 2001

Age | Population | Proportion distribution (weight) | Standard million
Total | 274,634,000 | 1.000000 | 1,000,000
Under 1 year | 3,795,000 | 0.013818 | 13,818
1–4 years | 15,192,000 | 0.055317 | 55,317
5–14 years | 39,977,000 | 0.145565 | 145,565
15–24 years | 38,077,000 | 0.138646 | 138,646
25–34 years | 37,233,000 | 0.135573 | 135,573
35–44 years | 44,659,000 | 0.162613 | 162,613
45–54 years | 37,030,000 | 0.134834 | 134,834
55–64 years | 23,961,000 | 0.087247 | 87,247
65–74 years | 18,136,000 | 0.066037 | 66,037
75–84 years | 12,315,000 | ^†^0.044842 | 44,842
85 years and over | 4,259,000 | 0.015508 | 15,508

† Figure is rounded up instead of down to force total to 1.0.

SOURCE: National Center for Health Statistics. Anderson RN, Rosenberg HM. Age standardization of death rates: Implementation of the year 2000 standard. National Vital Statistics Reports; vol 47 no 3. Hyattsville, MD: National Center for Health Statistics. 1998. Available from: https://www.cdc.gov/nchs/data/nvsr/nvsr47/nvs47_03.pdf.

Age-adjusted rates are calculated by the direct method, as follows:

∑_i = 1_^n^ r_i_ × ( p_i_ / P ) The sum of I equals 1 to N, R sub I, times, open bracket, rho sub I divided by P, close bracket.

where

- r_i_ = rate in age group i in the population of interest
- p_i_ = standard population in age group i
- P = ∑_i = 1_^n^ p_i_ P equals the sum of I equals 1 to N, rho sub I.
- n = total number of age groups over the age range of the age-adjusted rate.

Age adjustment by the direct method requires the use of a standard age distribution. The standard for age-adjusting death rates and estimates from surveys in Health, United States is the projected year 2000 U.S. resident population. Starting with Health, United States, 2000, the projected year 2000 U.S. standard population replaced the 1970 civilian noninstitutionalized population for age-adjusting estimates from most National Center for Health Statistics (NCHS) surveys; and starting with Health, United States, 2001, it was used uniformly and replaced the 1940 U.S. population for age-adjusting mortality statistics and the 1980 U.S. resident population, which previously had been used for age-adjusting estimates from the National Health and Nutrition Examination Survey.

Changing the standard population has implications for racial and ethnic differentials in mortality. For example, the mortality ratio for the black to white populations is reduced from 1.6 using the 1940 standard to 1.4 using the 2000 standard, reflecting the greater weight the 2000 standard gives to the older population, in which race differentials in mortality are smaller.

Age-adjusted estimates from any data source presented in Health, United States that use the projected year 2000 U.S. resident population may differ from age-adjusted estimates based on the same data presented in other reports if different age groups are used in the adjustment procedure.

For more information on implementing the 2000 population standard for age-adjusting death rates, see: Anderson RN, Rosenberg HM. Age standardization of death rates: Implementation of the year 2000 standard. National Vital Statistics Reports; vol 47 no 3. Hyattsville, MD: National Center for Health Statistics. 1998. Available from: https://www.cdc.gov/nchs/data/nvsr/nvsr47/nvs47_03.pdf. For more information on the derivation of age-adjustment weights for use with NCHS survey data, see: Klein RJ, Schoenborn CA. Age adjustment using the 2000 projected U.S. population. Healthy People 2010 statistical notes, no 20. Hyattsville, MD: National Center for Health Statistics. 2001. Available from: https://www.cdc.gov/nchs/data/statnt/statnt20.pdf. The projected year 2000 U.S. standard population is available from the National Cancer Institute’s Surveillance, Epidemiology, and End Results (SEER) Program: https://seer.cancer.gov/stdpopulations/stdpop.singleages.html.

Mortality data—Death rates are age-adjusted to the projected year 2000 U.S. standard population (Table I). Prior to 2001 data, age-adjusted rates were calculated using standard million proportions based on rounded population numbers (Table II). Starting with 2001 data, unrounded population numbers are used to adjust age. Adjustment is based on 11 age groups, with two exceptions. First, age-adjusted death rates for black males and black females in 1950 are based on nine age groups, with under 1 and 1-4 combined as one group, and 75-84 and 85 and over combined as one group. Second, age-adjusted rates for years of potential life lost before age 75 also use the projected year 2000 standard population and are based on eight age groups: under 1, 1-14, 15-24, and 10-year age groups through 65-74.

National Health and Nutrition Examination Survey (NHANES)—Estimates based on the National Health Examination Survey and NHANES are generally age-adjusted to the projected year 2000 U.S. standard population using five age groups: 20-34, 35-44, 45-54, 55-64, and 65-74 or 65 and over (Table I). Prior to Health, United States, 2001, these estimates were age-adjusted to the 1980 U.S. resident population.

National Health Care Surveys—Estimates based on the National Ambulatory Medical Care Survey and the National Hospital Ambulatory Medical Care Survey are age-adjusted to the projected year 2000 U.S. standard population (Table I). Information on the age groups used in the age-adjustment procedure is contained in the footnotes of the specific Health, United States trend tables.

National Health Interview Survey (NHIS)—Estimates based on NHIS are age-adjusted to the projected year 2000 U.S. standard population (Table I). Prior to Health, United States, 2000, NHIS estimates were age-adjusted to the 1970 civilian noninstitutionalized population Information on the age groups used in the age-adjustment procedure is contained in the footnotes of the specific tables.

## AIDS

See Appendix II, Acquired immunodeficiency syndrome (AIDS).

## Alcohol consumption

Measured differently in the following data systems. (Also see Appendix II, Binge drinking.)

Monitoring the Future (MTF) Study—This school-based survey of secondary school students collects information on alcohol use by using self-completed questionnaires. To determine whether they have tried alcohol in their lifetime, students are asked a preliminary alcohol consumption screening question: “Have you ever had any alcoholic beverage to drink—more than just a few sips?” where alcoholic beverage is defined as beer, wine, liquor, and any other beverage that contains alcohol. Students who reply in the affirmative are then asked additional questions about their alcohol consumption over different time frames: “On how many occasions (if any) have you had alcohol to drink—more than just a few sips… in your lifetime,… in the last 12 months,… in the last 30 days?” A subsequent question asks, “Think back over the last two weeks. How many times have you had five or more drinks in a row?” A drink is defined as a bottle of beer, a glass of wine, a shot glass of liquor, a mixed drink, etc.

National Survey on Drug Use and Health (NSDUH)—Asks respondents aged 12 and over about their alcohol use in the 30 days before the interview. Current alcohol use is defined as any use of alcohol in the past 30 days.

In addition to asking about any alcohol use, NSDUH collects information on binge alcohol use and heavy alcohol use, which are not mutually exclusive categories.

## Any-listed diagnosis

See Appendix II, Diagnosis.

## Average annual rate of change (percent change)

In Health, United States, average annual rates of change, or growth rates, are calculated as follows:

[ ( P_n_ / P_o_ )^1 / N^ − 1 ] × ​ 100 Open square bracket, open bracket, P sub N divided by P sub O, close bracket, all to 1 divided by N, minus 1, close square bracket, times 100.

where

- P_n_ = later time period
- P_o_ = earlier time period
- N = number of years in interval.

This geometric rate of change assumes that a variable increases or decreases at the same rate during each year between the two time periods.

## Average length of stay

The American Hospital Association computes average length of stay by dividing the number of inpatient days by the number of admissions. (Also see Appendix II, Days of care; Discharge; Inpatient.)

## Bed, health facility

The American Hospital Association defines bed count as the number of beds, cribs, and pediatric bassinets that are set up and staffed for use by inpatients on the last day of the reporting period. In the Centers for Medicare & Medicaid Service’s Quality Improvement Evaluation System (formerly the Online Survey Certification and Reporting System), all beds in certified facilities are counted on the day of certification inspection. (Also see Appendix II, Hospital; Occupancy rate.)

## Binge drinking

Measured in the following data systems. (Also see Appendix II, Alcohol consumption.)

Monitoring the Future (MTF) Study—This school-based survey of secondary school students collects information on alcohol use by using self-completed questionnaires. To determine whether they have tried alcohol, students are asked a preliminary screening question: “Have you ever had any alcoholic beverage to drink—more than just a few sips?” where alcoholic beverage is defined as beer, wine, liquor, and any other beverage that contains alcohol. Students who reply in the affirmative are then asked additional questions about their alcohol consumption, including one on binge drinking: “Think back over the last two weeks. How many times have you had five or more drinks in a row?” A drink is defined as a bottle of beer, a glass of wine, a shot glass of liquor, a mixed drink, etc. Information on binge drinking is obtained for 12th graders (starting in 1975) and for 8th and 10th graders (starting in 1991).

National Survey on Drug Use and Health (NSDUH)—Asks respondents aged 12 and over about their alcohol use in the 30 days before the interview. Until 2015, the threshold for binge alcohol use was defined the same for males and females: drinking five or more drinks on the same occasion on at least 1 day in the past 30 days. Since 2015, the definition remains the same for males, while binge alcohol use for females has been lowered to drinking four or more drinks on the same occasion on at least 1 day in the past 30 days. Due to this definition change, recent data on binge alcohol use among women cannot be compared with estimates prior to 2015

Heavy alcohol use is defined as binge drinking on 5 or more days in the past 30 days. Because heavy alcohol users are binge alcohol users by definition, estimates of heavy alcohol use among females also were affected by the 2015 question revision, and recent estimates are not comparable with data collected prior to 2015.

## Birth cohort

Consists of all persons born within a given period of time, such as a calendar year.

## Birth rate

See Appendix II, Rate: Birth and related rates.

## Birthweight

The first weight of the newborn obtained after birth. Low birthweight is defined as weighing less than 2,500 grams (5 lb 8 oz). Very low birthweight is defined as weighing less than 1,500 grams (3 lb 4 oz). Prior to 1979, low birthweight was defined as weighing 2,500 grams or less, and very low birthweight as weighing 1,500 grams or less.

## Blood pressure, high

See Appendix II, Hypertension.

## Body mass index (BMI)

A measure that adjusts body weight for height. It is calculated as weight in kilograms divided by height in meters squared. Normal weight for adults is defined as BMI of 18. 5 to 24. 9; overweight but not obese is defined as BMI of 25. 0 to 29. 9; and obesity is BMI greater than or equal to 30.0. Within the obesity category, Grade 1 obesity is defined as BMI of 30.0 to 34.9; Grade 2 is BMI of 35.0 to 39. 9; and Grade 3 is BMI of greater than or equal to 40.0. Prior to assigning a person to a BMI category, BMI is rounded to one decimal place. In Health, United States, the National Health and Nutrition Examination Survey variable Body Mass Index is used to assign persons to BMI categories. Pregnant females were excluded from analyses. Mobile examination center (MEC) weights were used to obtain estimates. However, for the 1988-1994 estimates for adults, almost 500 persons had an abbreviated examination in their home instead of going to the MEC. The MEC + home weight was used to include these persons in the estimates.

For more information on the BMI cut points for adults, see: National Heart, Lung, and Blood Institute. Managing overweight and obesity in adults: Systematic evidence review from the Obesity Expert Panel. 2013. Available from: https://www.nhlbi.nih.gov/health-pro/guidelines/in-develop/obesity-evidence-review; Jensen MD, Ryan DH, Apovian CM, Ard JD, Comuzzie AG, Donato KA, et al. 2013 AHA/ACC/TOS guideline for the management of overweight and obesity in adults: A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines and the Obesity Society. Circulation 129(25 Suppl 2):S102-38. 2014. Available from: https://www.ncbi.nlm.nih.gov/pubmed/24222017; U.S. Department of Health and Human Services. Healthy People 2020: Nutrition, physical activity, and obesity. 2012. Available from: https://www.healthypeople.gov/2020/leading-health-indicators/2020-lhi-topics/Nutrition-Physical-Activity-and-Obesity.

Obesity for children and adolescents is defined as BMI at or above the sex- and age-specific 95th percentile from the 2000 Centers for Disease Control and Prevention Growth Charts (https://www.cdc.gov/growthcharts/). The age used is age in months at the time of examination. Also see: Kuczmarski RJ, Ogden CL, Guo SS, Grummer-Strawn LM, Flegal KM, Mei Z, et al. 2000 CDC Growth Charts for the United States: Methods and development. National Center for Health Statistics. Vital Health Stat 11(246). 2002. Available from: https://www.cdc.gov/nchs/data/series/sr_11/sr11_246.pdf.

MEC weights were used to obtain estimates. Pregnant females were excluded from analyses. Starting with Health, United States, 2010, the terminology describing excess weight among children changed from previous editions. The term “obesity” now refers to children who were formerly labeled as overweight. This is a change in terminology only and not a change in measurement. For more information, see: Ogden CL, Flegal KM. Changes in terminology for childhood overweight and obesity. National Health Statistics Reports; no 25. Hyattsville, MD: National Center for Health Statistics. 2010. Available from: https://www.cdc.gov/nchs/data/nhsr/nhsr025.pdf.

## Cause of death

For the purpose of national mortality statistics, every death is attributed to one underlying condition, based on information reported on the death certificate and using the international rules for selecting the underlying cause of death from the conditions stated on the certificate. The underlying cause is defined by the World Health Organization as “the disease or injury that initiated the train of events leading directly to death, or the circumstances of the accident or violence that produced the fatal injury.” Generally, more medical information is reported on death certificates than is directly reflected in the underlying cause of death. Conditions that are not selected as the underlying cause of death constitute the nonunderlying causes of death, also known as multiple cause of death.

Cause of death is coded according to the appropriate revision of the International Classification of Diseases (ICD) (Table III). Effective with deaths occurring in 1999, the United States began using the 10th revision of ICD (ICD-10); during the period 1979-1998, causes of death were coded and classified according to the 9th revision (ICD-9). Table IV lists ICD codes for the 6th through 10th revisions for causes of death shown in Health, United States. In Health, United States, common terms are sometimes used in the text in place of medical terminology. Examples include “cancer” for “malignant neoplasm” and “kidney disease” for “nephritis, nephrotic syndrome and nephrosis.”

Table III Revision of the International Classification of Diseases (ICD), by year of conference in which adopted and years in use in the United States

ICD revision | Year of conference in which revision adopted | Years in use in United States
1st | 1900 | 1900–1909
2nd | 1909 | 1910–1920
3rd | 1920 | 1921–1929
4th | 1929 | 1930–1938
5th | 1938 | 1939–1948
6th | 1948 | 1949–1957
7th | 1955 | 1958–1967
8th | 1965 | 1968–1978
9th | 1975 | 1979–1998
10th | 1990 | 1999–present

SOURCE: NCHS. Available from: https://www.cdc.gov/nchs/icd/icd9.htm.

Each ICD revision has produced discontinuities in cause-of-death trends. These discontinuities are measured by using comparability ratios that are essential to the interpretation of mortality trends. For further discussion, see: https://www.cdc.gov/nchs/nvss/mortality/comparability_icd.htm. (Also see Appendix II, Comparability ratio; International Classification of Diseases [ICD]; and Appendix I, National Vital Statistics System [NVSS]; Multiple Cause-of-Death File.)

## Cause-of-death ranking

Selected causes of death of public health and medical importance are compiled into tabulation lists and are ranked according to the number of deaths assigned to these causes. The top-ranking causes determine the leading causes of death. Certain causes on the tabulation lists are not ranked if, for example, the category title represents a group title (such as “Major cardiovascular diseases” and “Symptoms, signs, and abnormal clinical and laboratory findings, not elsewhere classified”) or the category title begins with the words “Other” or “All other.” In addition, when one of the titles that represents a subtotal (such as “Malignant neoplasms”) is ranked, its component parts are not ranked. The tabulation lists used for ranking in the 10th revision of the International Classification of Diseases (ICD-10) include the List of 113 Selected Causes of Death, which replaces the ICD-9 List of 72 Selected Causes, HIV Infection and Alzheimer’s Disease; and the ICD-10 List of 130 Selected Causes of Infant Death, which replaces the ICD-9 List of 60 Selected Causes of Infant Death and HIV Infection. Causes that are tied receive the same rank; the next cause is assigned the rank it would have received had the lower-ranked causes not been tied, that is, a rank is skipped. For more information, see the annual series of “Deaths: Final Data” and “Deaths: Leading Causes” reports, available from: https://www.cdc.gov/nchs/products/nvsr.htm. (Also see Appendix II, International Classification of Diseases [ICD].)

## Children’s Health Insurance Program

Title XXI of the Social Security Act, often referred to as the Children’s Health Insurance Program (CHIP), is a program originally enacted by the Balanced Budget Act of 1997. The Children’s Health Insurance Program Reauthorization Act of 2009 (CHIPRA, P.L. 111-3) reauthorized CHIP and appropriated funding for CHIP through FY 2013. The Affordable Care Act of 2010 (ACA, P.L. 111-148) extended CHIP funding through FY 2015, and the Medicare Access and CHIP Reauthorization Act of 2015 (P.L. 114-10) extended funding with no programmatic changes for CHIP through 2017. A 6-year reauthorization of CHIP was signed into law on January 22, 2018, extending the program through the end of fiscal year 2023. On February 9, 2018, the Bipartisan Budget Act was signed into law, extending CHIP an additional 4 years. Therefore, CHIP is currently authorized through 2027

CHIP provides federal funds for states to provide health care coverage to eligible low-income, uninsured children whose income is too high to qualify for Medicaid. Generally, CHIP is only available through age 18. CHIP gives states broad flexibility in program design within a federal framework that includes important beneficiary protections. Funds from CHIP may be used for a separate child health program or to expand Medicaid. Although CHIP is not part of Medicaid, in some instances in Health, United States, data on CHIP and Medicaid are presented together, and those instances are discussed in the footnotes of the respective tables. For more information, see: https://www.medicaid.gov/chip/index.html. (Also see Appendix II, Health insurance coverage; Medicaid.)

## Cholesterol

Serum total cholesterol is a combination of high-density lipoprotein (HDL) cholesterol, low-density lipoprotein (LDL) cholesterol, and very low-density lipoprotein (VLDL) cholesterol. High serum total cholesterol is a risk factor for cardiovascular disease (see: Wilson PW, D’Agostino RB, Levy D, Belanger AM, Silbershatz H, Kannel WB. Prediction of coronary heart disease using risk factor categories. Circulation 97(18):1837-47. 1998). In its first report (1988) on high blood cholesterol, the National Cholesterol Education Program Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults provided guidelines for the treatment of high blood cholesterol, defined as a serum total cholesterol value greater than or equal to 240 mg/dL (6. 20 mmol/L). This definition was also used in the panel’s second and third reports. A more recent set of guidelines—the result of initial efforts by the National Heart, Lung, and Blood Institute and subsequent efforts by the American College of Cardiology and the American Heart Association—focused on which groups of people could benefit from statin use based on their risk factors. Because Health, United States focuses on providing population-level prevalence data rather than individual-level estimates, three broad indicators of cholesterol are presented based on measured serum total cholesterol level and the reported use of cholesterol-lowering medications Cholesterol levels are determined using the National Health and Nutrition Examination

Table IV Cause-of-death codes, by applicable revision of the International Classification of Diseases (ICD)

Cause of death (10th revision titles) | 6th and 7th revisions | 8th revision | 9th revision | 10th revision
Communicable diseases | ... | ... | 001–139, 460–466, 480–487, 771.3 | A00–B99, J00–J22
Chronic and noncommunicable diseases | ... | ... | 140–459, 470–478, 490–799 | C00–I99, J30–R99
Meningococcal infection | ... | ... | 036 | A39
Septicemia | ... | ... | 038 | A40–A41
Human immunodeficiency virus (HIV) disease^1^ | ... | ... | *042–*044 | B20–B24
Malignant neoplasms | 140–205 | 140–209 | 140–208 | C00–C97
Colon, rectum, and anus | 153–154 | 153–154 | 153, 154 | C18–C21
Trachea, bronchus, and lung | 162–163 | 162 | 162 | C33–C34
Breast | 170 | 174 | 174–175 | C50
Prostate | 177 | 185 | 185 | C61
In situ neoplasms, benign neoplasms, and neoplasms of uncertain or unknown behavior | 210–239 | 210–239 | 210–239 | D00–D48
Diabetes mellitus | 260 | 250 | 250 | E10–E14
Anemias | ... | ... | 280–285 | D50–D64
Meningitis | ... | ... | 320–322 | G00, G03
Alzheimer’s disease | ... | ... | 331.0 | G30
Diseases of heart | 400–402, 410–443 | 390–398, 402, 404, 410–429 | 390–398, 402, 404, 410–429 | I00–I09, I11, I13, I20–I51
Ischemic heart disease | ... | ... | 410–414, 429.2 | I20–I25
Essential hypertension and hypertensive renal disease | ... | ... | ... | I10, I12, I15
Cerebrovascular diseases | 330–334 | 430–438 | 430–434, 436–438 | I60–I69
Atherosclerosis | ... | ... | 440 | I70
Influenza and pneumonia^2^ | 480–483, 490–493 | 470–474, 480–486 | 480–487 | J09–J18
Chronic lower respiratory diseases | 241, 501, 502, 527.1 | 490–493, 519.3 | 490–494, 496 | J40–J47
Chronic liver disease and cirrhosis | 581 | 571 | 571 | K70, K73–K74
Nephritis, nephrotic syndrome and nephrosis | ... | ... | 580–589 | N00–N07, N17–N19, N25–N27
Pregnancy, childbirth, and the puerperium | 640–689 | 630–678 | 630–676 | O00–O99
Congenital malformations, deformations and chromosomal abnormalities | ... | ... | 740–759 | Q00–Q99
Certain conditions originating in the perinatal period | ... | ... | 760–779 | P00–P96
Newborn affected by maternal complications of pregnancy | ... | ... | 761 | P01
Newborn affected by complications of placenta, cord and membranes | ... | ... | 762 | P02
Disorders related to short gestation and low birthweight, not elsewhere classified | ... | ... | 765 | P07
Birth trauma | ... | ... | 767 | P10–P15
Intrauterine hypoxia and birth asphyxia | ... | ... | 768 | P20–P21
Respiratory distress of newborn | ... | ... | 769 | P22
Bacterial sepsis of newborn | ... | ... | ... | P36
Necrotizing enterocolitis of newborn | ... | ... | 777.5 | P77
Sudden infant death syndrome | ... | ... | 798.0 | R95
Injuries^2^ | ... | ... | E800–E869, E880–E929, E950–E999 | *U01–*U03, V01–Y36, Y85–Y87, Y89
Unintentional injuries^3^ | E800–E936, E960–E965 | E800–E929, E940–E946 | E800–E869, E880–E929 | V01–X59, Y85–Y86
Motor vehicle-related injuries^3^ | E810–E835 | E810–E823 | E810–E825 | V02–V04, V09.0, V09.2, V12–V14, V19.0–V19.2, V19.4–V19.6, V20–V79, V80.3–V80.5, V81.0–V81.1, V82.0–V82.1, V83–V86, V87.0–V87.8, V88.0–V88.8, V89.0, V89.2
Poisoning | E870–E888, E890–E895 | E850–E877 | E850–E869 | X40–X49
Suicide^2^ | E963, E970–E979 | E950–E959 | E950–E959 | *U03, X60–X84, Y87.0
Homicide^2^ | E964, E980–E983 | E960–E969 | E960–E969 | *U01–*U02, X85–Y09, Y87.1
Firearm-related injury | ... | E922, E955, E965, E970, E985 | E922, E955.0–E955.4, E965.0–E965.4, E970, E985.0–E985.4 | *U01.4, W32–W34, X72–X74, X93–X95, Y22–Y24, Y35.0
Injury by drug overdose | ... | ... | ... | X40–X44, X60–64, X85, Y10–Y14
Any opioid | ... | ... | ... | X40–X44, X60–64, X85, Y10–Y14 (underlying cause) and T40.0–T40.4, T40.6 (multiple cause)
Heroin | ... | ... | ... | X40–X44, X60–64, X85, Y10–Y14 (underlying cause) and T40.1 (multiple cause)
Natural and semisynthetic opioids | ... | ... | ... | X40–X44, X60–64, X85, Y10–Y14 (underlying cause) and T40.2 (multiple cause)
Methadone | ... | ... | ... | X40–X44, X60–64, X85, Y10–Y14 (underlying cause) and T40.3 (multiple cause)
Other synthetic opioids (other than methadone) | ... | ... | ... | X40–X44, X60–64, X85, Y10–Y14 (underlying cause) and T40.4 (multiple cause)

... Category not applicable. Cause-of-death codes are not provided for causes not shown in Health, United States.

1 Categories for coding human immunodeficiency virus (HIV) infection were introduced in 1987. The asterisk (*) indicates codes that are not part of ICD–9.

2 Starting with 2001 data, the National Center for Health Statistics (NCHS) introduced categories *U01–*U03 for classifying and coding deaths due to acts of terrorism. The asterisk (*) indicates codes that are not part of ICD–10. Starting with 2007 data, NCHS introduced the category J09 for coding avian influenza virus. In 2009, the title for the ICD–10 code J09 was changed from “Influenza due to identified avian influenza virus” to “Influenza due to certain identified influenza virus.” This change was made to accommodate deaths from influenza A (H1N1) virus in the ICD–10 code J09 for data years 2009 and beyond.

3 In the public health community, the term “unintentional injuries” is preferred to accidents, and the term “motor vehicle-related injuries” is preferred to motor vehicle accidents.

SOURCE: NCHS. Advance report: Final mortality statistics, 1974. Monthly Vital Statistics Report; vol 24 no 11 suppl. Hyattsville, MD: National Center for Health Statistics. 1976. Available from: https://www.cdc.gov/nchs/data/mvsr/supp/mv24_11sacc.pdf; Hoyert DL, Kochanek KD, Murphy SL. Deaths: Final data for 1997. National Vital Statistics Reports; vol 47 no 19. Hyattsville, MD: National Center for Health Statistics. 1999. Available from: https://www.cdc.gov/nchs/data/nvsr/nvsr47/nvs47_19.pdf; Hoyert DL, Heron MP, Murphy SL, Kung HC. Deaths: Final data for 2003. National Vital Statistics Reports; vol 54 no 13. Hyattsville, MD: National Center for Health Statistics. 2006. Available from: https://www.cdc.gov/nchs/data/nvsr/nvsr54/nvsr54_13.pdf; Murphy SL, Xu JQ, Kochanek KD. Deaths: Final data for 2010. National Vital Statistics Reports; vol 61 no 4. Hyattsville, MD: National Center for Health Statistics. 2013. Available from: https://www.cdc.gov/nchs/data/nvsr/nvsr61/nvsr61_04.pdf; Xu JQ, Murphy SL, Kochanek KD, Bastian B, Arias E. Deaths: Final data for 2016. National Vital Statistics Reports; vol 67. Hyattsville, MD: National Center for Health Statistics. 2018. Available from: https://www.cdc.gov/nchs/products/nvsr.htm.

Surveys (NHANES) T_CHOL file. For more information on the current cholesterol guidelines, see: National Heart, Lung, and Blood Institute. Management of blood cholesterol in adults: Systematic evidence review from the Cholesterol Expert Panel. 2013. Available from: https://www.nhlbi.nih.gov/health-pro/guidelines/in-develop/cholesterol-in-adults; and Stone NJ, Robinson JG, Lichtenstein AH, Merz CN, Blum CB, Eckel RH, et al. 2013 ACC/AHA guideline on the treatment of blood cholesterol to reduce atherosclerotic cardiovascular risk in adults: A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. Circulation 129:(25 Suppl 2) S1-45. 2014. Available from: http://circ.ahajournals.org/content/129/25_suppl_2/S1.full.

In Health, United States, three measures of total cholesterol are presented: hypercholesterolemia, high serum total cholesterol, and mean serum total cholesterol. Hypercholesterolemia is based on both laboratory testing and self-reported use of cholesterol-lowering medication. It is defined as measured serum total cholesterol greater than or equal to 240 mg/dL (6.20 mmol/L) or reporting taking cholesterol-lowering medications. Respondents who were told by a doctor or health professional that their cholesterol was high, were told by a doctor to take cholesterol-lowering medication, and who answered “yes” to the question, “Are you now following this advice to take prescribed medicine?” were classified as taking cholesterol-lowering medication. High serum total cholesterol is defined as measured serum total cholesterol greater than or equal to 240 mg/dL (6.20 mmol/L). Both high serum total cholesterol and mean serum total cholesterol are based on serum samples collected during the NHANES examination.

As part of the NHANES examination, venous blood serum samples collected from NHANES participants at mobile examination centers were frozen and shipped on dry ice to the laboratory conducting the lipid analyses. Serum total cholesterol was measured on all examined adults regardless of whether they had fasted, and data were analyzed regardless of fasting status. Cholesterol measurements are standardized according to the criteria of the Centers for Disease Control and Prevention (CDC)—and later the CDC-National Heart, Lung, and Blood Institute Lipids Standardization Program—to ensure comparable and accurate measurements. For more information, see: Myers GL, Cooper GR, Winn CL, Smith SJ. The Centers for Disease Control-National Heart, Lung, and Blood Institute Lipid Standardization Program: An approach to accurate and precise lipid measurements. Clin Lab Med 9(1):105-35. 1989. A detailed summary of the procedures used for measurement of total cholesterol in earlier NHANES years has been published in: Carroll MD, Kit BK, Lacher DA, Shero ST, Mussolino ME. Trends in lipids and lipoproteins in US adults, 1988-2010. JAMA 308(15):1545-54. 2012. A description of the laboratory procedures for the total cholesterol measurement for different NHANES years is published by the National Center for Health Statistics and is available from: https://www.cdc.gov/nchs/nhanes/index.htm.

## Cigarette smoking

Estimates of cigarette smoking among adults and youths from several sources are presented in Health, United States. In addition, cigarette smoking may be considered in estimates of the use of tobacco products. (For information on how cigarette smoking is defined for estimates in Health, United States, see Appendix II, Tobacco use.)

## Civilian noninstitutionalized population; Civilian population

See Appendix II, Population.

## Colorectal tests or procedures

Used to detect polyps, abnormal cell growth, lesions, and other gastrointestinal conditions, including colon cancer. These tests may include home fecal occult blood tests (FOBT), sigmoidoscopy, or colonoscopy. The time interval between screenings varies, depending on the type of test as well as individual risk factors and prior screening history.

In the National Health Interview Survey (NHIS), questions about colorectal tests or procedures were asked of respondents aged 40 and over on an intermittent schedule, and the questions varied over time. Colorectal screening tests and procedures may be used for diagnostic or screening purposes, but the purpose cannot be determined from NHIS

In 2000, 2003, 2005, and 2008, respondents were asked, “Have you ever had a sigmoidoscopy, colonoscopy, or proctoscopy?” In 2010, 2013, and 2015, respondents were asked two separate questions: “Have you ever had a colonoscopy?” and “Have you ever had a sigmoidoscopy?” An additional question about colorectal testing, “Have you ever had a blood stool test using a home testing kit?” was asked in all of these survey years.

Respondents who replied that they had a colorectal test or procedure were asked subsequent questions about the month, year, and time since their most recent test or procedure. In 2000 and 2003, if respondents did not provide the year of, or the time since, their most recent colorectal examination, they were asked about the time frame of their most recent examination (i.e., whether they had the examination a year ago or less, more than 1 year ago but not more than 2 years ago, more than 2 years ago but not more than 3 years ago, more than 3 years ago but not more than 5 years ago, more than 5 years ago but not more than 10 years ago, or more than 10 years ago). For adults who provided the year, but not the month, of their most recent examination, the examination date was coded as July 15 of the provided year.

In 2005, 2008, 2010, 2013, and 2015, the questionnaire skip pattern was modified so that respondents giving an incomplete or partial date (missing month or year) of their most recent colorectal examination were asked a follow-up question about the time since their most recent examination (i.e., whether they had the examination a year ago or less, more than 1 year ago but not more than 2 years ago, more than 2 years ago but not more than 3 years ago, more than 3 years ago but not more than 5 years ago, more than 5 years ago but not more than 10 years ago, or more than 10 years ago). In 2015, the home FOBT questions were modified to include fecal immunochemical tests (FITs)—a type of FOBT (“Have you ever had a blood stool or FIT test, using a home test kit?”). In 2010 and 2015, additional questions on the use of virtual or CT colonoscopy were included in the questionnaire, but these questions were not used to determine whether respondents had a colorectal test or procedure in Health, United States.

In Health, United States, adults aged 50-75 were considered to have any colorectal test or procedure if they met the 2008 screening guidelines made by the U.S. Preventive Services Task Force (USPSTF). These adults either reported (a) a home FOBT in the past year, (b) a sigmoidoscopy procedure in the past 5 years with FOBT in the past 3 years, or (c) a colonoscopy in the past 10 years.

The current USPSTF recommendations—made in 2016—have not been applied to Health, United States estimates. These guidelines recommend the use of screening in adults aged 50 to 75, with frequency of screening varying by test and procedure. Recommended strategies include: (1) annual or biennial screening with guaiac-based FOBT (gFOBT) in addition to flexible sigmoidoscopy every 3 to 5 years, (2) annual screening with FITs, (3) screening every 10 years with colonoscopy, or (4) screening every 5 years with CT colography. The recommendation does not emphasize a particular screening approach, as the risks and benefits may vary. For a summary of current colorectal screening recommendations and the status of the review of the guidelines, see: https://www.uspreventiveservicestaskforce.org/Page/Document/UpdateSummaryFinal/colorectal-cancer-screening2

## Community hospital

See Appendix II, Hospital.

## Comparability ratio

About every 10 to 20 years, the International Classification of Diseases (ICD) is revised to stay abreast of advances in medical science and changes in medical terminology. Each of these revisions produces breaks in the continuity of cause-of-death statistics because of changes in classification and in the rules for selecting an underlying cause of death. Classification and rule changes affect cause-of-death trend data by shifting deaths away from some cause-of-death categories and into others. Comparability ratios measure the effect of changes in classification and coding rules. For the causes shown in Table V, comparability ratios range between 0.6974 and 1. 5812. Influenza and pneumonia had the lowest comparability ratio (0.6974), indicating that this cause is about 30% less likely to be selected as the underlying cause of death under the 10th revision of ICD (ICD-10) than under the 9th revision (ICD-9). Alzheimer’s disease had the highest comparability ratio (1. 5812), indicating that Alzheimer’s disease is 58% more likely to be selected as the underlying cause when ICD-10 coding is used For selected causes of death, the ICD-9 codes used to calculate death rates for 1980-1998 differ from the ICD-9 codes most nearly comparable with the corresponding ICD-10 cause-of-death category, which also affects the ability to compare death rates across ICD revisions. Examples of these causes are Ischemic heart disease; Cerebrovascular diseases; Trachea, bronchus, and lung cancer; Unintentional injuries; and Homicide. To address this source of discontinuity, mortality trends for 1980-1998 were recalculated using ICD-9 codes that are more comparable with codes for corresponding ICD-10 categories. Table IV shows the ICD-9 codes used for these causes. This modification may lessen the discontinuity between the 9th and 10th revisions, but the effect on the discontinuity between the 8th and 9th revisions is not measured.

Comparability ratios shown in Table V are based on a comparability study in which the same deaths were coded using both the 9th and 10th revisions The comparability ratio was calculated by dividing the number of deaths classified using ICD-10 by the number of deaths classified using ICD-9. The resulting ratios represent the net effect of the 10th revision on cause-of-death statistics and can be used to adjust mortality statistics for causes of death classified by the 9th revision to be comparable with cause-specific mortality statistics classified by the 10th revision.

Table V Comparability of selected causes of death between the 9th and 10th revisions of the International Classification of Diseases (ICD)

Cause of death^1^ | Final comparability ratio^2^
Human immunodeficiency virus (HIV) disease | 1.0821
Malignant neoplasms | 1.0093
Colon, rectum, and anus | 0.9988
Trachea, bronchus, and lung | 0.9844
Breast | 1.0073
Prostate | 1.0144
Diabetes mellitus | 1.0193
Alzheimer’s disease | 1.5812
Diseases of heart | 0.9852
Ischemic heart diseases | 1.0006
Essential (primary) hypertension and hypertensive renal disease | 1.1162
Cerebrovascular diseases | 1.0502
Influenza and pneumonia | 0.6974
Chronic lower respiratory diseases | 1.0411
Chronic liver disease and cirrhosis | 1.0321
Nephritis, nephrotic syndrome and nephrosis | 1.2555
Pregnancy, childbirth, and the puerperium | 1.1404
Unintentional injuries | 1.0251
Motor vehicle-related injuries | 0.9527
Poisoning | 1.0365
Suicide | 1.0022
Homicide | 1.0020
Firearm-related injury | 1.0012
Chronic and noncommunicable diseases | 1.0100
Injuries | 1.0159

1 See Table IV in this report for ICD-9 and ICD-10 cause-of-death codes.

2 Ratio of number of deaths classified by ICD-10 to number of deaths classified by ICD-9.

SOURCE: NCHS. Table 1. Final and preliminary comparability ratios for 113 selected causes of death. Available from: ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Datasets/Comparability/icd9_icd10/Comparability_Ratio_tables.xls; Miniño AM, Anderson RN, Fingerhut LA, Boudreault MA, Warner M. Deaths: Injuries, 2002. National Vital Statistics Reports; vol 54 no 10. Hyattsville, MD: National Center for Health Statistics. 2006. Available from: https://www.cdc.gov/nchs/data/nvsr/nvsr54/nvsr54_10.pdf.

The application of comparability ratios to mortality statistics helps make the analysis of change between 1998 and 1999 more accurate and complete. The 1998 comparability-modified death rate is calculated by multiplying the comparability ratio by the 1998 death rate. Comparability-modified rates should be used to estimate mortality change between 1998 and 1999.

Caution should be used when applying the comparability ratios presented in Table V to age-, race-, and sex-specific mortality data. Demographic subgroups may sometimes differ with regard to their cause-of-death distribution, and this would result in demographic variation in cause-specific comparability ratios.

For more information, see: Anderson RN, Miniño AM, Hoyert DL, Rosenberg HM. Comparability of cause of death between ICD-9 and ICD-10: Preliminary estimates. National Vital Statistics Reports; vol 49 no 2. Hyattsville, MD: National Center for Health Statistics. 2001. Available from: https://www.cdc.gov/nchs/data/nvsr/nvsr49/nvsr49_02.pdf; Kochanek KD, Smith BL, Anderson RN. Deaths: Preliminary data for 1999. National Vital Statistics Reports; vol 49 no 3. Hyattsville, MD: National Center for Health Statistics. 2001. Available from: https://www.cdc.gov/nchs/data/nvsr/nvsr49/nvsr49_03.pdf; Final ratios for 113 selected causes of death, available from: ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Datasets/Comparability/icd9_icd10/; and the ICD comparability ratio website at: https://www.cdc.gov/nchs/nvss/mortality/comparability_icd.htm. (Also see Appendix II, Cause of death; International Classification of Diseases [ICD].)

## Compensation

See Appendix II, Employer costs for employee compensation.

## Consumer Price Index (CPI)

A measure of the average change in prices of goods and services purchased by urban households. The CPI is prepared by the U.S. Bureau of Labor Statistics. The medical care component of CPI shows trends in medical care prices based on specific indicators of hospital, medical, and drug prices. A revised definition of CPI has been in use since January 1988. (Also see Appendix II, Gross domestic product [GDP]; and Health expenditures, national.)

## Contraception

The National Survey of Family Growth (NSFG) collects information on contraceptive use as reported by women aged 15-44. To determine current contraceptive use, women were asked to identify up to four contraceptive methods they had used during the month of interview from a list of contraceptive methods. In the 2011-2015 NSFG, these methods included birth control pill, condom, male sterilization, female sterilization, withdrawal, injectables, hormonal implants, calendar rhythm, natural family planning, diaphragm, female condom or vaginal pouch, foam, jelly or cream, cervical cap, suppository or insert, sponge, intrauterine device, emergency contraception, contraceptive patch, contraceptive ring, or other methods. Contraceptive methods listed in the 2011-2015 survey may differ from contraceptive methods listed in previous NSFG surveys depending on which methods were available during each survey period.

## Cost-to-charge ratio

The Agency for Healthcare Research and Quality’s Healthcare Cost and Utilization Project (HCUP) contains data on total charges per discharge as reported on the hospital discharge record. This charge information represents the amount the hospital billed for services, but it does not reflect how much hospital services actually cost or the specific amounts that hospitals received in payment. Data on costs may be of more interest to some users. The HCUP cost-to-charge ratio files convert charges to costs. Each file contains hospital-specific cost-to-charge ratios based on all-payer inpatient cost for nearly every hospital in HCUP. Cost information was obtained from hospital cost reports collected by the Centers for Medicare & Medicaid Services. Some imputations for missing values were necessary. These files are unique by year.

## Critical access hospital

See Appendix II, Hospital.

## Crude birth rate; Crude death rate

See Appendix II, Rate: Birth and related rates; Rate: Death and related rates.

## Data presentation standards for proportions

Health, United States, 2017 adopts newly developed data presentation standards for proportions (usually multiplied by 100 and expressed as percentages) for selected National Center for Health Statistics (NCHS) data sources and years The new multistep standards are described in the report, “National Center for Health Statistics Data Presentation Standards for Proportions.” This multistep approach is based on minimum denominator sample sizes, the absolute and relative widths of a 95% confidence interval calculated using the Clopper-Pearson method and adapted for complex surveys by Korn and Graubard, and degrees of freedom. Using these standards, estimates identified as statistically unreliable (or whose complementary proportions are unreliable) are suppressed (or flagged). This approach was chosen because it performs well for proportions near 0 or 1, incorporates information from the complex survey design including the effective sample sizes, and is generally conservative (i.e., a 95% Clopper-Pearson confidence interval includes the true proportion more than 95% of the time).

This multistep approach was identified after a review of current standards, the purpose and scope of the data collection, and advances in statistical methodology. The use of the Korn-Graubard modification of the Clopper-Pearson confidence interval for proportions is considered an improvement over the commonly used Wald confidence interval, which is known for its undercoverage (i.e., a 95% Wald confidence interval includes the true proportion less than 95% of the time).

In Health, United States, 2017 this multistep approach has been applied to estimates in the 2015-2016 and 2013-2016 National Health and Nutrition Examination Surveys, the 2016 National Health Interview Survey, and the 2014-2015 National Ambulatory Medical Care Survey. The reliability of estimates for prior data years was evaluated based on relative standard errors.

For more information on the newly developed multistep approach, see: Parker JD, Talih M, Malec DJ, Beresovsky V, Carroll M, Gonzalez Jr JF, et al. National Center for Health Statistics data presentation standards for proportions. Hyattsville, MD: National Center for Health Statistics. Vital Health Stat 2(175). 2017. Available from: https://www.cdc.gov/nchs/data/series/sr_02/sr02_175.pdf. (Also see Appendix II, Relative standard error [RSE].)

## Days of care

Defined by the American Hospital Association as the number of adult and pediatric days of care rendered during the entire reporting period. Days of care for newborns are excluded. (Also see Appendix II, Admission; Average length of stay; Discharge; Hospital; Hospital utilization; Inpatient.)

## Death rate

See Appendix II, Rate: Death and related rates.

## Dental caries

Evidence of decay on the crown or enamel surface of a tooth (i.e., coronal caries), including treated and untreated caries Untreated dental caries refers to decay on the crown or enamel surface of a tooth (i.e., coronal caries) that has not been treated or filled. Decay in the root (i.e., root caries) was not included.

In Health, United States, estimates on the presence of caries are based on evaluation of primary and permanent teeth for persons aged 5 and over The third molars were not included. Persons without at least one natural tooth (primary or permanent) were classified as edentulous (without any teeth) and were excluded. The majority of edentulous persons are aged 65 and over Estimates of edentulism among persons aged 65 and over were 33% in 1988-1994, 23% in 2005-2008, and 17% in 2011-2014.

Dental caries was identified by an oral examination as part of the National Health and Nutrition Examination Survey (NHANES). Over time, there have been changes in the NHANES oral health examination process, ages examined, and methodology. During 1988-1994, a full-mouth complete oral health examination was conducted by a trained dentist on those aged 1 and over. During 1999-2004, a full-mouth complete oral health examination was conducted by a trained dentist on those aged 2 and over. During 2005-2008, data were collected for those aged 5 and over by a trained health technologist using the Basic Screening Examination (BSE), a simplified screening process to collect information on untreated caries, dental restorations, and dental sealants. During 2009-2010, the BSE was conducted by a trained dental hygienist on those aged 3-19. No data on adults were collected. During 2005-2008 and 2009-2010, the use of the BSE does not allow analysts to determine if untreated decay was found in permanent teeth or primary teeth. For 2011-2014 data, a full-mouth complete oral health examination was conducted by a trained dentist on those aged 1 and over.

For more information, see: Dye BA, Barker LK, Li X, Lewis BG, Beltrán-Aguilar ED. Overview and quality assurance for the oral health component of the National Health and Nutrition Examination Survey (NHANES), 2005-08. J Public Health Dent 71(1):54-61. 2011, and the following NHANES resources: https://wwwn.cdc.gov/nchs/nhanes/2007-2008/OHX_E.htm, https://wwwn.cdc.gov/nchs/nhanes/2009-2010/OHXDEN_F.htm, and https://wwwn.cdc.gov/nchs/nhanes/2013-2014/OHXDEN_H.htm.

## Dental visit

Starting in 1997, National Health Interview Survey respondents were asked, “About how long has it been since you last saw or talked to a dentist? Include all types of dentists, such as orthodontists, oral surgeons, and all other dental specialists as well as hygienists.” Starting in 2001, the question was modified slightly to ask respondents how long it had been since they last saw a dentist. Questions about dental visits were not asked for children under age 2 for years 1997-1999 and under age 1 for years 2000 and beyond. Starting with 1997 data, estimates are presented for people with a dental visit in the past year.

## Diabetes

A group of conditions in which insulin is not adequately secreted or utilized. Diabetes is a leading cause of disease and death in the United States. Using data from the National Health and Nutrition Examination Survey (NHANES), three measures of diabetes are presented in Health, United States: physician-diagnosed diabetes, undiagnosed diabetes, and total diabetes. Physician-diagnosed diabetes data were obtained by self-report. Respondents who answered “yes” to the question, “Other than during pregnancy, have you ever been told by a doctor or health professional that you have diabetes or sugar diabetes?” were classified as having physician-diagnosed diabetes.

Only respondents who were not classified as having physician-diagnosed diabetes were evaluated to determine if they had undiagnosed diabetes. Undiagnosed diabetes was based on the results of laboratory testing of whole blood and blood plasma samples collected from NHANES participants at mobile examination centers Undiagnosed diabetes was defined as a fasting plasma glucose (FPG) of at least 126 mg/dL or a hemoglobin A1c of at least 6.5% among those without reported physician diagnosis. Participants examined in the morning had fasted for at least 8 hours and less than 24 hours at the time of the blood draw. Estimates in the current edition of Health, United States may differ from prior editions, since those may have only included participants who had fasted for at least 9 hours and less than 24 hours.

Fasting is not necessary to measure hemoglobin A1c. However, to be consistent with the subsample of fasting participants used for FPG, assessment of undiagnosed diabetes in Health, United States is limited to the fasting subsample. Total diabetes includes those who were classified as having either physician-diagnosed or undiagnosed diabetes. Morning fasting sample weights were used to estimate the prevalence of diagnosed, undiagnosed, and total diabetes, and pregnant women were excluded.

Starting with Health, United States, 2010, an elevated hemoglobin A1c (greater than or equal to 6. 5%) was included as a component of the definition of undiagnosed diabetes, along with FPG. Previous editions of Health, United States did not evaluate hemoglobin A1c to classify participants as having undiagnosed diabetes; undiagnosed diabetes was based solely on elevated FPG (greater than or equal to 126 mg/dL) among those without physician-diagnosed diabetes. The revised definition of undiagnosed diabetes was based on recommendations from the American Diabetes Association (ADA) Hemoglobin A1c was recommended as a component in diagnosing diabetes because improvements in assay standardization make A1c results more reliable. In addition, research provided evidence linking elevated A1c levels with diabetic complications, thus allowing for a threshold to be set—a threshold above which patients would be diagnosed as having diabetes. Although ADA recommends using hemoglobin A1c greater than or equal to 6.5% as an indicator of undiagnosed diabetes, it cautions that A1c may be misleading in individuals with certain blood disorders (including sickle cell trait), which may have specific ethnic or geographic distributions. Therefore, clinicians may use other criteria and tests to diagnose a specific patient. For more information, see: Diagnosis and classification of diabetes mellitus. Diabetes Care 38(Suppl 1):S8-S16. 2015; Standards of medical care in diabetes—2010. Diabetes Care 33(Suppl 1):S11-S61. 2010; and International Expert Committee Report on the role of the A1c assay in the diagnosis of diabetes. Diabetes Care 32(7):1327-34. 2009. To ensure data comparability over time, the revised definition of undiagnosed diabetes was applied to all estimates shown in Health, United States. As expected, this revised definition increased the percentage of participants classified as having undiagnosed diabetes.

Periodically, NHANES laboratory testing is performed at different laboratories using different instruments than testing in earlier years. In those instances, NHANES conducts crossover studies to evaluate the impact of these changes on laboratory measurements, and thus their impact on the evaluation of data over time. Crossover studies have been conducted to evaluate the impact of laboratory changes on both FPG and A1c. In order to account for laboratory changes for 2005-2006 to the present, the recommended adjustments to FPG have been incorporated in estimates presented in Health, United States so that these estimates are compatible with those from earlier years. NHANES does not recommend any adjustments to the A1c data.

Estimates presented in Health, United States may differ from other estimates based on the same data and presented elsewhere if different weights, age-adjustment groups, definitions, or trend adjustments are used.

For more information, see: https://wwwn.cdc.gov/Nchs/Nhanes/2013-2014/GHB_H.htm, and https://wwwn.cdc.gov/Nchs/Nhanes/2013-2014/GLU_H.htm.

## Diagnosis

The act or process of identifying or determining the nature and cause of a disease or injury through evaluation of patient history, examination of a patient, and review of laboratory data. Diagnoses in the National Ambulatory Medical Care Survey (NAMCS) and the National Hospital Ambulatory Medical Care Survey (NHAMCS) are abstracted from medical records and are currently coded according to the International Classification of Diseases, 9th Revision, Clinical Modification (ICD-9-CM). Starting with 2016 data, diagnosis data will be classified using the International Classification of Diseases, 10th Revision, Clinical Modification/Procedure Coding System (ICD-10-CM/PCS).

For a given medical care encounter, the first-listed diagnosis can be used to categorize the visit, or if more than one diagnosis is recorded on the medical record, the visit can be categorized based on all diagnoses recorded Analyzing first-listed diagnoses avoids double-counting events such as visits or hospitalizations; the first-listed diagnosis is often, but not always, considered the most important or dominant condition among all comorbid conditions. However, the choice of the first-listed diagnosis by the medical facility may be influenced by reimbursement or other factors. (Also see Appendix II, External cause of injury; Injury; Injury-related visit.)

## Diagnostic and other nonsurgical procedure

See Appendix II, Procedure.

## Discharge

The National Health Interview Survey defines a hospital discharge as the completion of any continuous period of stay of one night or more in a hospital as an inpatient. According to the Healthcare Cost and Utilization Project—National (Nationwide) Inpatient Sample, a discharge is a completed inpatient hospitalization. A hospitalization may be completed by death or by release of the patient to the customary place of residence, a nursing home, another hospital, or other locations. (Also see Appendix II, Admission; Average length of stay; Days of care; Hospital utilization; Inpatient.)

## Dom iciliary care home

See Appendix II, Long-term care facility; Nursing home.

## Drug

Pharmaceutical agents, by any routes of administration, for the prevention, diagnosis, or treatment of medical conditions or diseases. Data on specific drug use are collected in several National Center for Health Statistics surveys. (Also see Appendix II, Multum Lexicon Plus therapeutic class.)

National Health and Nutrition Examination Survey (NHANES)—Drug information from NHANES III and from NHANES for 1999 and subsequent years was collected during in-person interviews conducted in participants’ homes. Starting with 2001 data, participants were asked whether they had taken medication in the past 30 days for which they needed a prescription. For 1988-1994 and 1999-2000, the question wording differed slightly; participants were asked whether they had taken a prescription medication in the past month. For all survey years, those who answered “yes” were asked to provide the prescription medication containers for the interviewer. For each medication reported, the interviewer entered the product’s complete name from the container. If no container was available, the interviewer asked the participant to verbally report the name of the medication. In addition, participants were asked how long they had been taking the medication and the main reason for use.

All reported medication names were converted to their standard generic ingredient name. For multi-ingredient products, the ingredients were listed in alphabetical order and counted as one drug (e.g., Tylenol #3 was listed as acetaminophen; codeine). No trade or proprietary names were provided on the data file.

Drug data from NHANES provide a snapshot of all prescribed drugs reported by a sample of the civilian noninstitutionalized population for a 30-day period (or past month, for earlier survey years). Drugs taken on an irregular basis, such as every other day, once per week, or for a 10-day period, were captured in the 30-day recall period. Data shown in Health, United States for the percentage of the population reporting multiple prescription drugs during the past 30 days include a range of drug utilization patterns; for example, persons who took three or more drugs daily during the past 30 days or persons who took a different drug three separate times would be classified as taking three or more drugs in the past 30 days, as long as at least three drugs were taken at some time during the past 30 days.

For more information on prescription drug data collection and coding in NHANES, see: https://wwwn.cdc.gov/Nchs/Nhanes/2013-2014/RXQ_RX_H.htm, and https://wwwn.cdc.gov/Nchs/Nhanes/1999-2000/RXQ_DRUG.htm.

For more information on NHANES III prescription drug data collection and coding, see: https://wwwn.cdc.gov/nchs/data/nhanes3/2a/pupremed.pdf. The small number of respondents (fewer than 10) who responded “unknown” to whether they were taking prescription medication was coded as not taking prescription drugs in the past month. (Also see Appendix I, National Health and Nutrition Examination Survey [NHANES].)

## Drug abuse

See Appendix II, Illicit drug use.

## Education

Several approaches to defining educational categories are used in Health, United States. Estimates are typically presented for adults aged 25 and over in order to give people time to complete their education.

National Health and Nutrition Examination Survey (NHANES)—In 1988-1994 (NHANES III) the questionnaire asked, “What is the highest grade or year of regular school [person] has completed?” Responses were used to categorize adults according to educational credentials (i.e., no high school diploma or GED; high school diploma or GED; some college, no bachelor’s degree; bachelor’s degree or higher). Starting with 1999-2000 data, the questionnaire was changed to ask, “What is the highest grade or level of school [you have/(person) has] completed or the highest degree you have/(person) has received?” For data on children, education is based on the level of education completed by the head of the household. The question asked is, “What is the highest grade or level of school [you have/(person) has] completed or the highest degree [you have/(person) has] received?”

National Health Interview Survey (NHIS)—Starting in 1997, the NHIS questionnaire was changed to ask, “What is the highest level of school [person] has completed or the highest degree received?” Responses were used to categorize adults according to educational credentials (i.e., no high school diploma or general educational development high school equivalency diploma [GED]; high school diploma or GED; some college, no bachelor’s degree; associate’s degree; bachelor’s degree or higher.)

Prior to 1997, the education variable in NHIS was measured by asking, “What is the highest grade or year of regular school [person] has ever attended?” and “Did [person] finish the grade/year?” Responses were used to categorize adults according to years of education completed (i.e., less than 12, 12, 13-15, or 16 years or more).

Data from the 1996 and 1997 NHIS were used to compare distributions of educational attainment for adults aged 25 and over, using categories based on educational credentials (1997) and categories based on years of education completed (1996). A larger percentage of persons reported some college than reported 13-15 years of education, and a correspondingly smaller percentage reported a high school diploma or GED than reported 12 years of education. In 1997, 19% of adults reported no high school diploma, 31% a high school diploma or GED, 26% some college, and 24% a bachelor’s degree or higher. In 1996, 18% of adults reported less than 12 years of education, 37% reported 12 years, 20% reported 13-15 years, and 25% reported 16 or more years of education.

## Emergency department

According to the National Hospital Ambulatory Medical Care Survey, an emergency department is a hospital facility that is staffed 24 hours a day and provides unscheduled outpatient services to patients whose condition requires immediate care Emergency services provided under the “hospital as landlord” arrangement were also eligible. An emergency department was eligible if it was staffed 24 hours a day. If an eligible emergency department had an emergency service area that was open less than 24 hours a day, then that area was included under the emergency department. If a hospital had an emergency department that was staffed less than 24 hours a day, that department was considered an outpatient clinic. (Also see Appendix II, Emergency department or emergency room visit; Outpatient department.)

## Emergency department or emergency room visit

Starting with the 1997 National Health Interview Survey, respondents to the Sample Adult questionnaire and the Sample Child questionnaire (a knowledgeable adult, usually a parent) were asked about the number of visits to hospital emergency rooms during the past 12 months, including visits that resulted in hospitalization. In the National Hospital Ambulatory Medical Care Survey, an emergency department visit is a direct personal exchange between a patient and either a physician or a health care provider working under the physician’s supervision, for the purpose of seeking care and receiving personal health services. (Also see Appendix II, Emergency department; Injury-related visit.)

## Employer costs for employee compensation

A measure of the average cost to employers for wages, salaries, and benefits per employee hour worked. Wages and salaries are defined as the hourly straight-time wage rate, or for workers not paid on an hourly basis, straight-time earnings divided by the corresponding hours. Straight-time wage and salary rates are total earnings before payroll deductions, excluding premium pay for work in addition to the regular work schedule (e.g., overtime, weekends, and holidays), shift differentials, and nonproduction bonuses such as discretionary holiday bonuses and lump-sum payments provided in lieu of wage increases. Production bonuses, incentive earnings, commission payments, and cost-of-living adjustments are included in straight-time wage and salary rates. Benefits included as compensation are paid leave (paid vacations, holidays, sick leave, and other leave), supplemental pay (premium pay for overtime, weekends, or holidays), shift differentials, nonproduction bonuses, insurance benefits (life, health, and short- and long-term disability), retirement and savings benefits (pension and other retirement plans and savings and th rift plans), and legally required benefits (Social Security, Medicare, federal and state unemployment insurance, and workers’ compensation). (Also see Appendix I, National Compensation Survey [NCS].)

## Ethnicity

See Appendix II, Hispanic origin.

## Exercise

See Appendix II, Physical activity, leisure-time.

## Expenditures

See Appendix II, Health expenditures, national. (Also see Appendix I, National Health Expenditure Accounts [NHEA].)

## External cause of injury

Used for classifying the circumstances in which injuries occur. The International Classification of Diseases, 9th Revision (ICD-9), External Cause of Injury Matrix, is a two-dimensional array describing both the mechanism or external cause of the injury (e.g., fall, motor-vehicle traffic) and the manner or intent of the injury (e.g., unintentional, self-inflicted, or assault). Although this matrix was originally developed for mortality, it has been adapted for use with the ICD-9 Clinical Modification (ICD-9-CM) and will be used in Health, United States until 2016 data are available. Data for 2016 and beyond will be classified using the International Classification of Diseases, 10th Revision, Clinical Modification/Procedure Coding System (ICD-10-CM/PCS). For more information, see the National Center for Health Statistics website at: https://www.cdc.gov/nchs/injury/injury_tools.htm; and see: Hedegaard HB, Johnson RL, Ballesteros MF. Proposed ICD-10-CM surveillance case definitions for injury hospitalizations and emergency department visits. National Health Statistics Reports; no 100. Hyattsville, MD: National Center for Health Statistics. 2017. Available from: https://www.cdc.gov/nchs/data/nhsr/NHSR100.pdf.

## Family income

For the National Health Interview Survey and the National Health and Nutrition Examination Survey, all people within a household who are related by blood, marriage or cohabitation, or adoption constitute a family. Each member of a family is classified according to the total income of the family. Unrelated individuals are classified according to their own income.

National Health and Nutrition Examination Survey (NHANES)—In NHANES 1999 and onward, family income is asked in a series of questions about possible sources of income, including wages, salaries, interest and dividends, federal programs, child support, rents, royalties, and other possible sources. After the information about sources of income was obtained in the family interview income section of the questionnaire, respondents were asked to report total combined family income for themselves and the other members of their family, in dollars. If respondents did not provide an answer or did not know the total combined family income, they were asked if the total family income was less than $20,000 or $20,000 or more. If respondents answered, a follow-up question asked them to select an income range from a list on a printed flash card. The midpoint of the income range was then used as the total family income value. Family income values are used to calculate a poverty measure. NHANES II (1976-1980) included questions on components of income; NHANES III (1988-1994) did not ask the detailed components-of-income questions but asked respondents to identify their income based on a set of ranges provided on a flash card. Family income was not imputed for individuals or families with no reported income information in any of the NHANES survey years. (Also see Appendix II, Poverty.)

National Health Interview Survey (NHIS)— Prior to 1997, family income was the total income received by members of a family (or by an unrelated individual) in the 12 months before the interview. Family income included wages, salaries, rents from property, interest, dividends, profits and fees from their own businesses, pensions, and help from relatives. Starting in 1997, NHIS collected family income data for the calendar year prior to the interview (e.g., 2015 family income data were based on calendar year 2014 information). The 1997-2006 instrument allowed the respondent to supply a specific dollar amount (up to $999,995). Any family income responses greater than $999,995 were entered as $999,996. Respondents who did not know or refused to give a dollar amount in response to this question were asked if their total combined family income for the previous year was $20,000 or more, or less than $20,000. If respondents answered this question, they were given one of two flash cards and asked to indicate which income group listed on the card best represented their family’s combined income during the previous calendar year. One flash card listed incomes that were $20,000 or more, and the other flash card listed incomes that were less than $20,000 Starting with the 2007 NHIS, the income amount follow-up questions that had been in place since 1997 were replaced with a series of unfolding bracket questions. The unfolding bracket method asked a series of closed-ended income range questions (e.g., “Is it less than $50,000?”) if the respondent did not provide an answer to the exact-income amount question. The closed-ended income range questions were constructed so that each successive question established a smaller range for the amount of the family’s income. In 2011, 2012, and 2014, the unfolding-bracket income questions were further refined to improve the assignment of poverty status.

For more information on this series of family income questions, see: NCHS. National Health Interview Survey 2015 Data release. 2016. Available from: https://www.cdc.gov/nchs/nhis/nhis_2015_data_release.htm.

Also see: Pleis JR, Cohen RA. Impact of income bracketing on poverty measures used in the National Health Interview Survey’s Early Release Program: Preliminary data from the 2007 NHIS. 2007. Available from: https://www.cdc.gov/nchs/data/nhis/income.pdf.

For NHIS respondents, family income data are used in the computation of a poverty measure. Starting with Health, United States, 2004, a new methodology for imputing family income data for NHIS was implemented for data years 1997 and beyond. Multiple imputations were performed for survey years 1997 and beyond, with five sets of imputed values created to allow for the assessment of variability caused by imputation. A detailed description of the multiple imputation procedure and data files for 1997 and beyond are available from: https://www.cdc.gov/nchs/nhis/quest_data_related_1997_forward.htm, through the “Data Release” or the “Imputed Income Files” link under that year. For data years 1990 through 1996, about 16% to 18% of persons had missing data for family income. In those years, missing values were imputed for family income using a sequential hot-deck, within-matrix, cells-imputation approach A detailed description of the imputation procedure and data files, with imputed annual family income for 1990 through 1996, is available from: ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Datasets/NHIS/1990-96_Family_Income/. (Also see Appendix II, Poverty; Table VII.)

National Immunization Survey (NIS)—Prior to 1998, family income was the total income received by all family members in the past 12 months at the time of interview. Following the changes in the NHIS income questions, NIS changed the reference period for 1998 onward and collected income received by all family members for the calendar year prior to the interview year for households with age-eligible children (e.g., 2016 NIS family income data are based on calendar year 2015 income). Family income is the combined total income received by all members of a family before taxes. For the family income questions, the household respondent is asked to include income received from jobs; Social Security; retirement income; unemployment payments; public assistance; interest; dividends; net income from business, farm, rent; or any other sources. Respondents who answered “don’t know” or refused to give a dollar amount for the total family income were asked a cascading sequence of income questions—a total of 15 cascading questions—that attempt to place the family income into 1 of 15 income intervals ranging from less than or equal to $7,500 to greater than or equal to $75,000. The initial question asks if the family income for the prior year was more or less than $20,000. Subsequent sets of income range questions are asked so that each successive question establishes a narrower income range.

A family income variable is constructed from the total family income question and the cascading income questions. If an exact income is given, family income is set to this amount; otherwise it is set to the midpoint of the tightest bounds established by the cascading-income questions. The values of total family income are used to calculate an income-to-poverty ratio. For NIS, this ratio is calculated only for households with age-eligible children, using either the actual family income value or the midpoint of the interval from the series of cascading questions in the numerator and the poverty threshold provided by the U.S. Census Bureau for the size of the family and the number of related children in the household in the denominator. Details of the income questions and computation of the income-to-poverty ratio for each data collection year can be found in the NIS data documentation (Data User’s Guide and Household Interview Questionnaire for NIS-Child and NIS-Teen), available from: https://www.cdc.gov/vaccines/imz-managers/nis/data-tables html.

For more information, see: Battaglia MP, Hoaglin DC, Izrael D, Khare M, Mokdad A. Improving income imputation by using partial income information and ecological variables. In: 2002 Proceedings of the American Statistical Association, Survey Research Methods Section. New York, NY. Available from: https://www.cdc.gov/nchs/data/nis/estimation_weighting/Battaglia2002.pdf.

Table VI High blood pressure in adults aged 20 and over, based on two definitions of high blood pressure: United States, 1999-2002 and 2013-2016

Characteristic | 1999-2002 | | 2013-2016
Characteristic | Systolic pressure of at least 140 mm Hg or diastolic pressure of at least 90 mm Hg^1^ | Systolic pressure of at least 130 mm Hg or diastolic pressure of at least 80 mm Hg^2^ | Systolic pressure of at least 140 mm Hg or diastolic pressure of at least 90 mm Hg^1^ | Systolic pressure of at least 130 mm Hg or diastolic pressure of at least 80 mm Hg^2^
20 years and over, age-adjusted^3^ | Percent
Both sexes | 19.9 | 42.9 | 14.9 | 34.0
Male | 19.1 | 47.5 | 16.6 | 38.2
Female | 20.2 | 37.7 | 13.1 | 29.7
Not Hispanic or Latino:
White only | 18.3 | 41.3 | 13.4 | 32.0
Black or African American only | 28.7 | 54.0 | 23.3 | 44.8
Asian only | - - - | - - - | 16.1 | 35.6
Hispanic or Latino | - - - | - - - | 15.4 | 34.5
Mexican origin | 21.6 | 41.1 | 15.6 | 34.4
20 years and over, crude
Both sexes | 19.9 | 43.1 | 16.0 | 35.6
Male | 18.2 | 46.8 | 17.0 | 38.8
Female | 21.6 | 39.5 | 15.1 | 32.6
Not Hispanic or Latino:
White only | 19.7 | 43.1 | 15.7 | 35.3
Black or African American only | 26.3 | 52.1 | 22.8 | 44.4
Asian only | - - - | - - - | 15.3 | 34.7
Hispanic or Latino | - - - | - - - | 12.5 | 30.7
Mexican origin | 13.9 | 31.9 | 12.7 | 30.5
20-44 years | 7.1 | 27.6 | 6.2 | 20.8
45-64 years | 23.0 | 52.0 | 18.2 | 42.7
65-74 years | 44.9 | 67.6 | 28.8 | 52.0
75 years and over | 59.1 | 75.6 | 42.2 | 61.0

- - - Data not available.

1 These blood pressure definitions are consistent with the National Heart, Lung, and Blood Institute. See: The seventh report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure. NIH publication no. 04-5230. 2004. Available from: https://www.nhlbi.nih.gov/guidelines/hypertension/jnc7full.pdf.

2 These definitions are based on guidelines released in October 2017 by the American College of Cardiology and the American Heart Association. These guidelines have lower standards for defining high blood pressure. Available from: http://www.acc.org/latest-in-cardiology/ten-points-to-remember/2017/11/09/11/41/2017-guideline-for-high-blood-pressure-in-adults.

3 Estimates are age-adjusted to the year 2000 standard population using five age groups: 20-34 years, 35-44 years, 45-54 years, 55-64 years, and 65 years and over.

NOTES: Estimates of high blood pressure do not take into consideration the use of antihypertensive medication. Percentages are based on the average of three blood pressure measurements taken. Pregnant women are excluded.

SOURCE: NCHS, National Health and Nutrition Examination Survey (NHANES).

## Federal hospital

See Appendix II, Hospital.

## Fee-for-service health insurance

Private (commercial) health insurance that reimburses health care providers on the basis of a fee for each health service provided to the insured person. In addition, “fee-for-service” is a term often applied to original Medicare, to distinguish it from Medicare managed-care plans and other new payment systems. (Also see Appendix II, Health insurance coverage; Managed care; Medicare.)

## Fertility rate

See Appendix II, Rate: Birth and related rates.

## Functional limitation

Health, United States, 2017 is adopting a measure of functional limitation based on six questions asked of persons aged 18 and over in the National Health Interview Survey (NHIS):

- Do you have difficulty seeing, even when wearing glasses?
- Do you have difficulty hearing, even when using your hearing aid(s)?
- Do you have difficulty walking or climbing steps?
- Using your usual language, do you have difficulty communicating, for example, understanding or being understood?
- Do you have difficulty remembering or concentrating?
- Do you have difficulty with self-care, such as washing all over or dressing?

Response categories are: no difficulty, some difficulty, a lot of difficulty, and cannot do at all/unable to do.

Table VII Imputed family income percentages in the National Health Interview Survey, by age and sex: United States, 1990-2016

Year | Both sexes | | | | | | | | | Females
Year | All ages | Under 18 years | 18 years and over | Under 65 years | 1-64 years | 18-64 years | 65 years and over | 2 years and over | 45 years and over | 18 years and over | 40 years and over
| Percent
1990 | 16 | 14 | 18 | 15 | 15 | 16 | 24 | 17 | 22 | 18 | 21
1991 | 18 | 15 | 19 | 17 | 17 | 17 | 26 | 18 | 23 | 19 | 23
1992 | 18 | 16 | 19 | 17 | 17 | 18 | 27 | 18 | 23 | 20 | 23
1993 | 16 | 14 | 17 | 15 | 15 | 16 | 23 | 16 | 20 | 17 | 19
1994 | 17 | 15 | 18 | 16 | 16 | 17 | 25 | 17 | 21 | 18 | 21
1995 | 16 | 14 | 16 | 15 | 15 | 15 | 22 | 16 | 19 | 17 | 19
1996 | 17 | 14 | 17 | 16 | 16 | 16 | 24 | 17 | 20 | 18 | 20
1997 | 24 | 21 | 26 | 23 | 23 | 24 | 34 | 25 | 30 | 26 | 30
1998 | 29 | 25 | 30 | 27 | 27 | 28 | 39 | 29 | 34 | 30 | 34
1999 | 31 | 27 | 32 | 29 | 29 | 30 | 43 | 31 | 37 | 33 | 37
2000 | 32 | 28 | 33 | 30 | 31 | 31 | 45 | 32 | 38 | 34 | 38
2001 | 32 | 27 | 33 | 30 | 30 | 31 | 44 | 32 | 38 | 34 | 37
2002 | 32 | 28 | 33 | 30 | 30 | 31 | 44 | 32 | 37 | 33 | 37
2003 | 33 | 30 | 35 | 32 | 32 | 33 | 44 | 34 | 38 | 35 | 38
2004 | 33 | 29 | 34 | 31 | 31 | 32 | 41 | 33 | 37 | 34 | 36
2005 | 33 | 29 | 34 | 31 | 31 | 32 | 44 | 33 | 38 | 35 | 37
2006 | 34 | 31 | 35 | 33 | 33 | 33 | 45 | 34 | 39 | 36 | 39
2007 | 33 | 29 | 34 | 31 | 31 | 32 | 43 | 33 | 37 | 35 | 38
2008 | 30 | 27 | 31 | 29 | 29 | 29 | 40 | 30 | 34 | 32 | 34
2009 | 25 | 21 | 26 | 23 | 23 | 24 | 34 | 25 | 29 | 26 | 29
2010 | 25 | 20 | 26 | 23 | 23 | 24 | 36 | 25 | 30 | 27 | 30
2011 | 22 | 19 | 23 | 21 | 21 | 22 | 31 | 23 | 26 | 24 | 26
2012 | 23 | 19 | 24 | 21 | 21 | 22 | 32 | 23 | 27 | 24 | 27
2013 | 23 | 19 | 24 | 22 | 22 | 23 | 31 | 23 | 27 | 25 | 27
2014 | 23 | 20 | 24 | 22 | 22 | 23 | 31 | 23 | 27 | 25 | 27
2015 | 23 | 20 | 24 | 22 | 22 | 22 | 31 | 23 | 26 | 24 | 26
2016 | 22 | 18 | 23 | 20 | 21 | 21 | 30 | 22 | 25 | 23 | 25

NOTES: Weighted percentages. See Appendix II, Family income.

SOURCE: NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Respondents with answers to one or more of the six questions were classified into one of three mutually exclusive categories. Those responding “a lot of difficulty” or “cannot do at all/unable to do” to at least one question were classified in the “A lot of difficulty/cannot do” category. Of the remaining, those responding “some difficulty” to at least one question were classified in the “some difficulty” category. Of the remaining, those responding “no difficulty” to at least one question were classified in the “no difficulty” category. During 2010-2016, 1% to 8% of respondents were excluded from the analysis because they were missing data across all six functioning questions. Data are for the civilian noninstitutionalized population. For more information on functional limitation, see: http://www.washingtongroup-disability.com.

These questions have been asked annually in NHIS starting in 2010, and are found in the 2010 Quality of Life NHIS files and the 2011-2016 Functioning and Disability NHIS files. For more information about NHIS, including annual questionnaire and documentation for these files, see: https://www.cdc.gov/nchs/nhis/data-questionnaires-documentation.htm.

## General hospital

See Appendix II, Hospital.

## Geographic region

The U.S. Census Bureau groups the 50 states and the District of Columbia, for statistical purposes, into four geographic regions (Northeast, Midwest, South, and West) and nine divisions based on geographic proximity; (see Figure).

## Gestation

For the National Vital Statistics System and the Centers for Disease Control and Prevention’s Abortion Surveillance System, the period of gestation is defined as beginning with the first day of the last normal menstrual period and ending with the day of birth or day of termination of pregnancy. Data on gestational age are subject to error for several reasons, including imperfect maternal recall or misidentification of the last menstrual period because of postconception bleeding, delayed ovulation, or intervening early miscarriage.

Figure U.S. Census Bureau: Four geographic regions and nine divisions of the United States

A map showing United States Census Bureau: Four geographic regions and nine divisions of the United States. The West region is made up of the Pacific and Mountain Divisions. Pacific Division: Washington, Oregon, California, Alaska, Hawai'i. The Midwest region is made up of the West North Central and East North Central Divisions. Mountain Division: Idaho, Montana, Wyoming, Nevada, Utah, Colorado, Arizona, New Mexico. West North Central Division: North Dakota, South Dakota, Nebraska, Kansas, Minnesota, Iowa, Montana. East North Central Division: Wisconsin, Illinois, Michigan, Indiana, Ohio. The South region is made up of the West South Centra, East South Central, and South Atlantic Divisions. West South Central Division: Oklahoma, Texas, Arkansas, Louisiana. East South Central Division: Missouri, Alabama, Tennessee, Kentucky. South Atlantic Division: Delaware, Maryland, West Virginia, Virginia, North Carolina, South Carolina, Georgia, Florida. The Northeast region is made up of Middle Atlantic and New England Divisions. Middle Atlantic: New York, New Jersey, Pennsylvania. New England: Maine, Vermont, New Hampshire, Massachusetts, Rhode Island, Connecticut.

## Gross domestic product (GDP)

The market value of the goods and services produced by labor and property located in the United States. As long as the labor and property are located in the United States, the suppliers (i.e., the workers, and for property, the owners) may be U.S. residents or residents of other countries. (Also see Appendix II, Consumer Price Index [CPI]; Health expenditures, national.)

## Health care contact

Starting in 1997, the National Health Interview Survey has collected information on health care contacts with doctors and other health care professionals using the following series of questions: “During the past 12 months, how many times have you gone to a hospital emergency room about your own health?;” “During the past 12 months, did you receive care at home from a nurse or other health care professional? What was the total number of home visits received?;” and “During the past 12 months, how many times have you seen a doctor or other health care professional about your own health at a doctor’s office, a clinic, or some other place? Do not include times you were hospitalized overnight, visits to hospital emergency rooms, home visits, or telephone calls.” Starting with 2000 data, this question was amended to specifically exclude dental visits.

For 1997-1999, for each question, respondents were shown a flash card with response categories of 0, 1, 2-3, 4-9, 10-12, or 13 or more visits. For tabulation of the 1997-1999 data, responses of 2-3 were recoded to 2, responses of 4-9 were recoded to 6, responses of 10-12 were recoded to 11, and 13 or more visits were recoded to 13. The recoded values for the three types of visits were then added to yield an estimate of total health care contacts. Starting with 2000 data, response categories were expanded to 0, 1, 2-3, 4-5, 6-7, 8-9, 10-12, 13-15, or 16 or more. For 2000 and more recent data, these response categories were recoded to the midpoint of the range. The category of 16 or more was recoded to 16. The recoded values for the three types of visits were then added to yield an estimate of the summary measure of health care contacts (including doctor’s visits, hospital emergency room visits, and home visits). After summing the three component visit variables, respondents with values on the edge of the categories presented in Health, United States were rounded down to provide a more conservative estimate of the number of visits. For example, a respondent with 3.5 health care contacts was included in the 1-3 visits category, and a respondent with 9.5 health care contacts was included in the 4-9 visits category Respondents were included in this analysis only if they were known on all three visit variables.

Analyses of the percentage of children without a health care visit are based on the following question: “During the past 12 months, how many times has [person] seen a doctor or other health care professional about [his/her] health at a doctor’s office, a clinic, or some other place? Do not include times [person] was hospitalized overnight, visits to hospital emergency rooms, home visits, or telephone calls.” Starting with 2000 data, this question was amended to specifically exclude dental visits. (Also see Appendix II, Emergency department or emergency room visit; Home visit.)

## Health expenditures, national

Estimates from the Centers for Medicare & Medicaid Services (CMS) that measure calendar year spending for health care in the United States by type of service delivered (e.g., hospital care, physician services, nursing home care) and source of funding for those services (e.g., private health insurance, Medicare, Medicaid, out-of-pocket spending). CMS produces both historical and projected estimates of health expenditures by category. (Also see Appendix I, National Health Expenditure Accounts [NHEA]; Appendix II, Gross domestic product [GDP].) Types of national health expenditures are described below.

Business, household, and other private expenditures—Outlays for services paid for by nongovernmental sources, such as consumers, private industry, and philanthropic and other nonpatient-care sources.

Government expenditures—Outlays for services paid for by federal, state, and local government agencies or expenditures required by governmental mandate (such as workers’ compensation insurance payments).

Health consumption expenditures—Outlays for goods and services relating directly to patient care, plus expenses for administering health insurance programs, the net cost of health insurance, and public health activities. This category is equivalent to total national health expenditures minus expenditures for investment in noncommercial research and structures and equipment.

Personal health care expenditures—Outlays for goods and services relating directly to patient care. These expenditures are total national health expenditures minus expenditures for investment, health insurance program administration and the net cost of insurance, and public health activities.

## Health insurance coverage

Broadly defined to include both public and private payers that cover medical expenditures incurred by a defined population in a variety of settings. Estimates of health insurance are available from several different government surveys. Because of differences in methodology, question wording, and recall period, estimates from different sources may vary and are not directly comparable. For more information, see: “Health Insurance Measurement and Estimates,” available from: https://www.census.gov/content/dam/Census/library/working-papers/2015/demo/2015-Vornovitsy-Day-01.pdf.

American Community Survey (ACS)—For point-in-time health insurance estimates, ACS respondents were asked about their coverage at the time of interview. Respondents were asked: “Is this person CURRENTLY covered by any of the following types of health insurance or health coverage plans? Mark yes or no for each type of coverage: Insurance through a current or former employer or union [of this person or another family member]; Insurance purchased directly from an insurance company [by this person or another family member]; Medicare, for people 65 and older, or people with certain disabilities; Medicaid, Medical Assistance, or any kind of government-assistance plan for those with low incomes or a disability; TRICARE or other military health care; VA [including those who have ever used or enrolled for VA health care]; Indian Health Service; any other type of health insurance or health coverage plan [specify plan].” In ACS, persons were considered uninsured if they were not covered by private health insurance, Medicare, Medicaid, Medical Assistance, TRICARE or other military health care, veteran’s coverage through the Veteran’s Administration, or other government coverage. People with Indian Health Service coverage only were considered uninsured in ACS

National Health Interview Survey (NHIS)—For point-intime health insurance estimates, NHIS respondents were asked about their coverage at the time of interview. For 1993-1996, respondents were asked about their coverage in the previous month. Questions on health insurance coverage were expanded starting in 1993, compared with previous years. In 1997, the entire questionnaire was redesigned and data were collected using a computer-assisted personal interview In 2007, questions on health insurance coverage were expanded again to include three new questions on high-deductible health plans, health savings accounts, and flexible spending accounts.

Respondents were considered to be covered by private health insurance if they indicated private health insurance, or prior to 1997, if they were covered by a single-service hospital plan. Private health insurance includes managed care such as health maintenance organizations.

Private insurance obtained through the workplace was defined as any private insurance that was originally obtained through a present or former employer or union, or starting in 1997, through the workplace, self-employment, or a professional association. Starting in 2011, respondents were also asked whether health insurance coverage was obtained through parents or another relative. Starting in 2014, an additional question on the Health Insurance Marketplace was added to the questionnaire for those respondents who did not indicate that their health plan was obtained through a present or former employer, union, self-employment, or professional association, to evaluate whether their plan was obtained through the Health Insurance Marketplace or state-based exchange Starting in 2015, an additional category “Through Healthcare.gov” was added to the list describing new options for the direct purchase of health insurance. Individuals who selected this new category did not receive the additional question about the Health Insurance Marketplace.

Until 1996, persons were defined as having Medicaid or other public assistance coverage if they indicated that they had either Medicaid or other public assistance or if they reported receiving Aid to Families with Dependent Children (AFDC) or Supplemental Security Income (SSI). After welfare reform in late 1996, Medicaid was delinked from AFDC and SSI. Starting in 1997, persons were considered to be covered by Medicaid if they reported Medicaid or a state-sponsored health program Starting in 1999, persons also were considered covered by Medicaid if they reported coverage by the Children’s Health Insurance Program. Medicare or military health plan coverage was also determined in the interview, and starting in 1997, other government-sponsored program coverage was determined as well.

If respondents did not report coverage under one of the types of plans listed above, and they had unknown coverage under either private health insurance or Medicaid, they were considered to have unknown coverage.

The remaining respondents without any indicated coverage were considered uninsured. The uninsured were persons who did not have coverage under private health insurance, Medicare, Medicaid, public assistance, a state-sponsored health plan, other government-sponsored programs, or a military health plan. Persons with only Indian Health Service (IHS) coverage were considered uninsured. Although NHIS respondents who report IHS coverage as their only source of coverage are currently recoded to being uninsured, IHS provides a comprehensive health service delivery system for approximately 2.2 million American Indian or Alaska Native persons; see: https://www.ihs.gov/newsroom/factsheets/ihsprofile/. Estimates of the percentage of persons who were uninsured based on NHIS may differ slightly from those based on other sources because of differences in survey questions, recall period, and other aspects of survey methodology.

In NHIS, on average less than 2% of people aged 65 and over reported no current health insurance coverage, but the small sample size precludes the presentation of separate estimates for this population. Therefore, the term “uninsured” refers only to the population under age 65

Two additional questions were added to the health insurance section of NHIS beginning with the third quarter of 2004 (Table VIII). One question was asked of persons aged 65 and over who had not indicated that they had Medicare: “People covered by Medicare have a card which looks like this. [Are/Is] [person] covered by Medicare?” The other question was asked of persons under age 65 who had not indicated any type of coverage: “There is a program called Medicaid that pays for health care for persons in need. In this state it is also called [state name]. [Are/Is] [person] covered by Medicaid?” Respondents who originally classified themselves as uninsured, but whose classification was changed to Medicare or Medicaid on the basis of a “yes” response to either question, subsequently received appropriate follow-up questions concerning periods of noncoverage for insured respondents. Of the 892 people (unweighted) who were eligible to receive the Medicare probe question in the third and fourth quarters of 2004, 55% indicated that they were covered by Medicare. Of the 9,146 people (unweighted) who were eligible to receive the Medicaid probe question in the third and fourth quarters of 2004, 3% indicated that they were covered by Medicaid. From 2004 onwards, estimates in Health, United States were calculated using the responses to the two additional probe questions. For a complete discussion of the effect of the addition of these two probe questions on the estimates for insurance coverage, see: Cohen RA, Martinez ME. Impact of Medicare and Medicaid probe questions on health insurance estimates from the National Health Interview Survey, 2004. Health E-Stats. National Center for Health Statistics. 2005. Available from: https://www.cdc.gov/nchs/data/hestat/impact04/impact04.htm.

Survey respondents may be covered by health insurance at the time of interview but may have experienced one or more lapses in coverage during the 12 months prior to interview Starting with Health, United States, 2006, NHIS estimates have been presented for the following three exhaustive categories: (a) people with health insurance continuously for the full 12 months prior to interview, (b) those who had a period of up to 12 months prior to interview without coverage, and (c) those who were uninsured for more than 12 months prior to interview This stub variable has been added to selected tables. Two additional NHIS questions were used to determine the appropriate category for the survey respondents: (a) all persons without a known comprehensive health insurance plan were asked, “About how long has it been since [person] last had health care coverage?”; and (b) all persons with known health insurance coverage were asked, “In the past 12 months, was there any time when [person] did NOT have ANY health insurance coverage?” Persons uninsured for 1 year are classified into the category “uninsured for a period of up to 12 months prior to interview “

For more information, see: Section V. Health insurance section (FHI). In: 2016 National Health Interview Survey (NHIS) public use data release: Survey description. 2017. Available from: ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Dataset_Documentation/NHIS/2016/srvydesc.pdf.

Table VIII Percentage of persons under age 65 with Medicaid or who are uninsured, by selected demographic characteristics, using Method 1 and Method 2 estimation procedures: United States, 2004

Characteristic | Medicaid^1^ | | Uninsured^2^
Characteristic | Method 2^3^ | Method 1^3^ | Method 2^3^ | Method 1^3^
Age | Percent (standard error)
Under 65 years | 12.0 (0.24) | 11.8 (0.24) | 16.4 (0.23) | 16.6 (0.23)
Under 18 years | 25.4 (0.49) | 24.9 (0.49) | 9.2 (0.30) | 9.7 (0.29)
18-64 years | 6.6 (0.17) | 6.5 (0.17) | 19.3 (0.26) | 19.4 (0.26)
Percent of poverty level^4^
Below 100% | 47.5 (1.03) | 46.6 (1.03) | 29.6 (0.89) | 30.5 (0.92)
100% to less than 200% | 22.0 (0.59) | 21.5 (0.60) | 28.9 (0.66) | 29.4 (0.66)
200% or more | 2.9 (0.13) | 2.8 (0.13) | 9.4 (0.23) | 9.5 (0.23)
Age and percent of poverty level^4^
Under 18 years
Below 100% | 71.9 (1.35) | 70.2 (1.35) | 14.5 (1.15) | 16.2 (1.22)
100% to less than 200% | 39.2 (1.13) | 38.4 (1.14) | 15.0 (0.81) | 15.8 (0.82)
200% or more | 6.2 (0.33) | 6.1 (0.33) | 4.9 (0.30) | 4.9 (0.30)
18-64 years
Below 100% | 31.2 (1.02) | 30.8 (1.02) | 39.7 (1.09) | 40.1 (1.09)
100% to less than 200% | 12.0 (0.48) | 11.8 (0.48) | 37.0 (0.72) | 37.2 (0.72)
200% or more | 1.7 (0.11) | 1.7 (0.10) | 11.0 (0.26) | 11.1 (0.26)
Hispanic origin and race^5^
Hispanic or Latino | 22.2 (0.55) | 21.5 (0.55) | 34.4 (0.64) | 35.1 (0.65)
Mexican | 22.0 (0.63) | 21.5 (0.63) | 37.6 (0.82) | 38.1 (0.83)
Not Hispanic or Latino | 10.2 (0.25) | 10.1 (0.25) | 13.2 (0.23) | 13.3 (0.23)
White only | 7.4 (0.26) | 7.4 (0.26) | 12.0 (0.25) | 12.1 (0.25)
Black or African American only | 23.9 (0.80) | 23.5 (0.79) | 17.3 (0.58) | 17.8 (0.58)

1 Includes persons who do not have private coverage but who have Medicaid or other state-sponsored health plans, including the Children’s Health Insurance Program (CHIP).

2 Includes persons who have not indicated that they are covered at the time of interview under private health insurance, Medicare, Medicaid, CHIP, a state-sponsored health plan, other government programs, or military health plan (includes VA, TRICARE, and CHAMP-VA). This category includes persons who are only covered by Indian Health Service (IHS) or only have a plan that pays for one type of service, such as accidents or dental care.

3 Starting with the third quarter of 2004, two additional questions were added to the National Health Interview Survey (NHIS) insurance section to reduce potential errors in age 65 with no reported coverage were asked explicitly about Medicaid coverage. Estimates calculated without using the additional information from these questions are noted as Method 1. Estimates calculated using the additional information from these questions are noted as Method 2.

4 Based on family income and family size and composition, using the U.S. Census Bureau’s poverty thresholds. The percentage of respondents with unknown poverty level was 28.2% in 2004. See the NHIS survey description for 2004. Available from: https://www.cdc.gov/nchs/data/nhis/srvydesc.pdf.

5 Persons of Hispanic origin may be of any race or combination of races. Similarly, the category Not Hispanic or Latino refers to all persons who are not of Hispanic or Latino origin, regardless of race.

SOURCE: NCHS, National Health Interview Survey, 2004, Family Core Component. Data are based on household interviews of a sample of the civilian noninstitutionalized population. For more information, see: Cohen RA, Martinez ME. Impact of Medicare and Medicaid probe questions on health insurance estimates from the National Health Interview Survey, 2004. National Center for Health Statistics. Health E-Stats. 2005. Available from: https://www.cdc.gov/nchs/data/hestat/impact04/impact04.htm. See Appendix I, National Health Interview Survey (NHIS).

(Also see Appendix II, Children’s Health Insurance Program [CHIP]; Fee-for-service health insurance; Health maintenance organization [HMO]; Managed care; Medicaid; Medicare; Uninsured.)

## Health maintenance organization (HMO)

A health care system that assumes or shares both the financial risks and the delivery risks associated with providing comprehensive medical services to a voluntarily enrolled population in a particular geographic area, usually in return for a fixed, prepaid fee. Pure HMO enrollees use only the prepaid, capitated health services of the HMO panel of medical care providers. Open-ended HMO enrollees use the prepaid HMO health services but may also receive medical care from providers who are not part of the HMO panel. There is usually a substantial deductible, copayment, or coinsurance associated with use of nonpanel providers. HMO model types are described below.

Group model HMO—An HMO that contracts with a single multispecialty medical group to provide care to the HMO’s membership. The group practice may work exclusively with the HMO, or it may provide services to non-HMO patients as well. The HMO pays the medical group a negotiated per capita rate, which the group distributes among its physicians, usually on a salaried basis.

Individual practice association (IPA)—A health care provider organization comprising a group of independent practicing physicians who maintain their own offices and band together for the purpose of contracting their services to HMOs, preferred provider organizations, and insurance companies. An IPA may contract with and provide services to both HMO and non-HMO plan participants.

Mixed model HMO—An HMO that combines features of more than one HMO model.

Network model HMO—An HMO that contracts with multiple physician groups to provide services to HMO members. It may include single or multispecialty groups.

Staff model HMO—A closed-panel HMO (where patients can receive services only through a limited number of providers) in which physicians are HMO employees. The providers see members in the HMO’s own facilities. (Also see Appendix II, Managed care; Preferred provider organization [PPO].)

## Health services and supplies expenditures

See Appendix II, Health expenditures, national.

## Health status, respondent-assessed

Health status was measured in the National Health Interview Survey by asking the family respondent about his or her health or the health of a family member: “Would you say [person’s] health in general is excellent, very good, good, fair, or poor?”

## Hearing trouble

In the National Health Interview Survey, information about hearing trouble is obtained by asking respondents how well they hear without the use of hearing aids. Prior to 2007 data, respondents were asked, “Which statement best describes your hearing without a hearing aid: good, a little trouble, a lot of trouble, or deaf?” Starting with 2007 data, the question was revised to expand the response categories. Respondents were asked, “These next questions are about your hearing WITHOUT the use of hearing aids or other listening devices. Is your hearing excellent, good, [do you have] a little trouble hearing, moderate trouble, a lot of trouble, or are you deaf?” Starting with 2008 data, respondents were asked, “WITHOUT the use of hearing aids or other listening devices, is your hearing excellent, good, [do you have] a little trouble hearing, moderate trouble, a lot of trouble, or are you deaf?” Because of the expanded response categories, 2007 and subsequent data are not strictly comparable with earlier years and caution is urged when interpreting trends. For example, in 2006, 3.5% of adults (aged 18 and over) were classified as having hearing difficulty (response categories: a lot of trouble or deaf). In 2007, 2.3% of adults (aged 18 and over) were classified as having hearing difficulty (response categories: a lot of trouble or deaf). This more than 30% decline from 2006 to 2007 in the estimate of those with hearing trouble is likely attributable to the addition of the moderate trouble response category, rather than changes in the prevalence of hearing trouble. Although all age groups saw a decline in the percentage reporting hearing trouble between 2006 and 2007, the amount of the decline varied. There was a 50% decline in reported hearing trouble among adults aged 18-44 (from 0. 8% in 2006 to 0.4% in 2007). Among adults aged 45-64, the percentage that reported hearing trouble declined 43%, from 3. 5% in 2006 to 2.0% in 2007. Among adults aged 65 and over, reported hearing trouble declined 24%, from 11.4% in 2006 to 8. 7% in 2007.

For more information, see: Pleis JR, Lucas JW. Summary health statistics for U.S. adults: National Health Interview Survey, 2007. National Center for Health Statistics. Vital Health Stat 10(240). 2009. Available from: https://www.cdc.gov/nchs/data/series/sr_10/sr10_240.pdf.

The questions about hearing trouble used to estimate hearing limitations are different than those used to assess the hearing component of the functional limitation measure. (Also see Appendix II, Functional limitation.)

## Hispanic origin

Hispanic or Latino origin includes persons of Mexican, Puerto Rican, Cuban, Central and South American, and other or unknown Latin American or Spanish origin. Persons of Hispanic origin may be of any race.

Birth file—The reporting area for a Hispanic-origin item on the birth certificate expanded between 1980 and 1993 (when the Hispanic item was included on the birth certificate in all states and the District of Columbia [D.C.]). Trend data on births of Hispanic and non-Hispanic parentage in Health, United States are affected by expansion of the reporting areas, which affects numbers of events, composition of the Hispanic population, and maternal and infant health characteristics.

In 1980 and 1981, information on births of Hispanic parentage was reported on the birth certificate by the following 22 states: Arizona, Arkansas, California, Colorado, Florida, Georgia, Hawaii, Illinois, Indiana, Kansas, Maine, Mississippi, Nebraska, Nevada, New Jersey, New Mexico, New York, North Dakota, Ohio, Texas, Utah, and Wyoming. In 1982 Tennessee, and in 1983 D.C., began reporting this information. Between 1983 and 1987, information on births of Hispanic parentage was available for 23 states and D.C. In 1988, this information became available for Alabama, Connecticut, Kentucky, Massachusetts, Montana, North Carolina, and Washington State, increasing the number of states reporting information on births of Hispanic parentage to 30 states and D.C. In 1989, this information became available from an additional 17 states, increasing the number of Hispanic-reporting states to 47 and D. C. In 1989, only Louisiana, New Hampshire, and Oklahoma did not report Hispanic parentage on the birth certificate. With the inclusion of Louisiana and Oklahoma in 1990 as Hispanic-reporting states, 99% of birth records included information on mother’s origin. Hispanic origin of the mother was reported on the birth certificates of 49 states and D.C. in 1991 and 1992; only New Hampshire did not provide this information. Starting in 1993, Hispanic origin of mother was reported by all 50 states and D.C.

Starting with 2003 data, some states began using the 2003 revision of the U.S. Standard Certificate of Live Birth. As of January 1, 2016, all states, D.C., Guam, Puerto Rico, the U.S. Virgin Islands, and the Northern Marianas had implemented the revised birth certificate of 2003. Hispanic origin and race are collected separately on the birth certificate The Hispanic-origin question on the 2003 revision of the birth certificate asks respondents to select only one response. Occasionally, more than one Hispanic-origin response is given; that is, a specified Hispanic-origin group (Mexican, Puerto Rican, Cuban, or Central and South American) in combination with one or more other specified Hispanic-origin groups. From 2003 through 2012, respondents who selected more than one Hispanic origin on the birth certificate were classified as other Hispanic. In 2012, 0.4% of births in the revised state-reporting area, plus Massachusetts (unrevised state that also reported more than one Hispanic-origin response), were to women reporting more than one Hispanic origin. Beginning with 2013 data, respondents who select more than one Hispanic origin are randomly assigned to a single Hispanic origin. The number of births to “other and unknown Hispanic” women increased by 1. 3% from 143,536 in 2015 to 145,381 in 2016, increasing steadily from 48,972 in 2003. Factors that may have influenced this rise are not clear but may include less specificity in respondent reporting of Hispanic origin and increases in the populations of groups included in the “other Hispanic” category. The Hispanic-origin question on the 1989 revision of the birth certificate also offers the opportunity to report more than one origin; however, National Center for Health Statistics (NCHS) processing guidelines for unrevised data allow for coding only the first Hispanic origin listed.

Linked birth/infant death file—Particularly useful for computing accurate infant mortality rates by race and Hispanic origin because the race and Hispanic origin of the mother from the birth certificate are used in both the numerator and denominator of the linked birth/infant death infant mortality rate. In contrast, infant mortality rates based on the vital statistics mortality file use for the numerator race and Hispanic origin as reported on the death certificate and for the denominator the race and Hispanic origin of the mother as reported on the birth certificate. Race and Hispanic-origin information from the birth certificate, which is reported by the mother, is considered more reliable than race and Hispanic-origin information from the death certificate, which is reported by the funeral director based on information provided by an informant or by observation. See “Birth file” and “Mortality file” in this section.

Mortality file—The reporting area for a Hispanic-origin item on the death certificate expanded between 1985 and 1997. In 1985, mortality data by Hispanic origin of decedent were based on deaths of residents in 17 states and D.C., whose data on the death certificate were at least 90% complete on a place-of-occurrence basis and of comparable format: Arizona, Arkansas, California, Colorado, Georgia, Hawaii, Illinois, Indiana, Kansas, Mississippi, Nebraska, New York, North Dakota, Ohio, Texas, Utah, and Wyoming. In 1986, New Jersey began reporting Hispanic origin of decedent, increasing the number of reporting states to 18 and D. C. in 1986 and 1987. In 1988, Alabama, Kentucky, Maine, Montana, North Carolina, Oregon, Rhode Island, and Washington State were added to the reporting area, increasing the number of states to 26 and D. C. In 1989, an additional 18 states were added, increasing the Hispanic-reporting area to 44 states and D.C.; only Connecticut, Louisiana, Maryland, New Hampshire, Oklahoma, and Virginia were not included in the reporting area. Starting with 1990 data in Health, United States, the criterion was changed to include states whose data were at least 80% complete. In 1990, Maryland, Virginia, and Connecticut; in 1991 Louisiana; and in 1993 New Hampshire were added, increasing the reporting area for Hispanic origin of decedent to 47 states and D.C. in 1990; 48 states and D.C. in 1991 and 1992; and 49 states and D.C. in 1993-1996. Only Oklahoma did not provide this information in 1993-1996. Starting in 1997, Hispanic origin of decedent was reported by all 50 states and D.C. Based on data from the U.S. Census Bureau, the 1990 reporting area encompassed 99. 6% of the U.S. Hispanic population. In 1990, more than 96% of death records included information on Hispanic origin of the decedent.

Starting with 2003 data, some states began using the 2003 revision of the U.S. Standard Certificate of Death, which allows the reporting of more than one race (multiple races) and includes some revisions in the item reporting Hispanic origin. The effect of the 2003 revision of the Hispanic-origin item on the reporting of Hispanic origin on death certificates is presumed to be minor For more information, see Appendix II, Race. Also see the Technical Notes sections of the annual series of “Deaths: Final Data” reports, available from: https://www.cdc.gov/nchs/products/nvsr.htm; and “NCHS Procedures for Multiple-Race and Hispanic Origin Data: Collection, Coding, Editing, and Transmitting,” available from: https://www.cdc.gov/nchs/data/dvs/Multiple_race_documentation_5-10-04.pdf.

National Health Interview Survey (NHIS) and National Health and Nutrition Examination Survey (NHANES)—Questions on Hispanic origin have been self-reported in NHIS since 1976 as well as in NHANES III and subsequent years of NHANES. Questions on Hispanic origin precede questions on race. For 1999-2006 data, the NHANES sample was designed to provide estimates specifically for persons of Mexican origin and not for all Hispanic-origin persons in the United States. Persons of Hispanic origin other than Mexican were entered into the sample with different selection probabilities that are not nationally representative of the total U.S. Hispanic population. Starting with 2007-2008 data collection, all Hispanic persons were oversampled, not just persons of Mexican origin. In addition to allowing estimates for the total group of Hispanic persons, the sample size for Hispanic persons of Mexican origin is sufficient to continue to produce reliable estimates for this group. However, the methodology for the oversampling of Hispanic persons did not provide sufficient sample sizes for calculating estimates for other Hispanic subgroups besides Mexican origin. For more information on the NHANES sampling methodology changes, see “National Health and Nutrition Examination Survey: Sample Design, 2011-2014,” available from: https://www.cdc.gov/nchs/data/series/sr_02/sr02_162.pdf; and the NHANES analytic guidelines available from: https://wwwn.cdc.gov/nchs/data/nhanes/2011-2012/analytic_guidelines_11_12.pdf.

For more information on race and Hispanic origin in NHIS, see the survey’s “Race and Hispanic Origin Information” page, available from: https://www.cdc.gov/nchs/nhis/rhoi.htm.

Surveillance, Epidemiology, and End Results (SEER) Program—SEER data are available from the National Institutes of Health, National Cancer Institute. SEER Hispanic data used in Health, United States tables exclude data from Alaska. The North American Association of Central Cancer Registries, Inc. (NAACCR) Hispanic Identification Algorithm was used on a combination of variables to classify incidence cases as Hispanic for analytic purposes. See: NAACCR guideline for enhancing Hispanic-Latino identification: Revised NAACCR Hispanic/Latino Identification Algorithm [NHIA v2. 2.1]. Revised 2011. Available from: https://www.naaccr.org/wp-content/uploads/2016/11/NHIA_v2_2_1_09122011.pdf.

Youth Risk Behavior Surveillance System (YRBSS)—Prior to 1999, a single question was asked about race and Hispanic origin, with the option of selecting one of the following categories: white not Hispanic, black not Hispanic, Hispanic or Latino, Asian or Other Pacific Islander, American Indian or Alaska Native, or other. Between 1999 and 2003, respondents were asked a single question about race and Hispanic origin with the option of choosing one or more of the following categories: white, black or African American, Hispanic or Latino, Asian, Native Hawaiian or Other Pacific Islander, or American Indian or Alaska Native. Beginning in 2005, respondents were asked a question about Hispanic origin (“Are you Hispanic or Latino?”) and a second separate question about race that included the option of selecting one or more of the following categories: American Indian or Alaska Native, Asian, black or African American, Native Hawaiian or Other Pacific Islander, or white. Because of the differences between questions, the data about race and Hispanic ethnicity for the years prior to 1999 are not strictly comparable with estimates for the subsequent years. However, analyses of data collected between 1991 and 2003 have indicated that the data are comparable across years and can be used to study trends. See Appendix II, Race; and see: Brener ND, Kann L, McManus T. A comparison of two survey questions on race and ethnicity among high school students Public Opin Q 67(2):227-36 2003.

## HIV

See Appendix II, Human immunodeficiency virus (HIV) disease.

## Home visit

Starting in 1997, the National Health Interview Survey has been collecting information on home visits received during the 12 months prior to interview Respondents are asked, “During the past 12 months, did you receive care at home from a nurse or other health care professional? What was the total number of home visits received?” These data are combined with data on visits to doctors’ offices, clinics, and emergency departments to provide a summary measure of adult health care visits. (Also see Appendix II, Emergency department or emergency room visit; Health care contact.)

## Hospital

According to the American Hospital Association (AHA), hospitals are licensed institutions with at least six beds whose primary function is to provide diagnostic and therapeutic patient services for medical conditions; they have an organized physician staff and provide continuous nursing services under the supervision of registered nurses. The World Health Organization (WHO) considers an establishment to be a hospital if it is permanently staffed by at least one physician, can offer inpatient accommodation, and can provide active medical and nursing care. Hospitals may be classified by type of service, ownership, size in terms of number of beds, and length of stay. In the National Hospital Ambulatory Medical Care Survey, hospitals include all those with an average length of stay for all patients of less than 30 days (short-stay) or hospitals whose specialty is general (medical or surgical) or children’s general. Federal hospitals and hospital units of institutions and hospitals with fewer than six beds staffed for patient use are excluded. (Also see Appendix II, Average length of stay; Bed, health facility; Days of care; Emergency department; Inpatient; Outpatient department.)

Community hospital—Based on the AHA definition, includes all nonfederal, short-term general, and special hospitals whose facilities and services are available to the public. Special hospitals include obstetrics and gynecology; eye, ear, nose, and throat; rehabilitation; orthopedic; and other specialty services. Short-term general and special children’s hospitals are also considered to be community hospitals. A hospital may include a nursing-home-type unit and still be classified as short-term, provided that the majority of its patients are admitted to units where the average length of stay is less than 30 days. Hospital units of institutions such as prisons and college infirmaries that are not open to the public and are contained within a nonhospital facility are not included in the category of community hospitals. Traditionally, the definition has included all nonfederal short-stay hospitals except facilities for persons with intellectual disabilities (formerly called mentally retarded). In a revised definition, the following additional sites were excluded: hospital units of institutions, and alcoholism and chemical dependency facilities.

Federal hospital—Those operated by the federal government

For-profit hospital—Those operated for profit by individuals, partnerships, or corporations.

General hospital—Those providing diagnostic, treatment, and surgical services for patients with a variety of medical conditions. According to WHO, these hospitals provide medical and nursing care for more than one category of medical discipline (e.g., general medicine, specialized medicine, general surgery, specialized surgery, and obstetrics). Excluded are hospitals, usually in rural areas, that provide a more limited range of care.

Nonprofit hospital—Those controlled by nonprofit organizations, such as religious organizations and fraternal societies

Registered hospital—Those registered with AHA. About 98% of U.S. hospitals are registered.

Short-stay hospital—In the National Health Interview Survey, short-stay hospitals are defined as any hospital or hospital department in which the type of service provided is general; maternity; eye, ear, nose, and throat; children’s; or osteopathic.

Special hospital—Those that provide a particular type of service to the majority of their patients. Special hospitals include psychiatric, tuberculosis, chronic disease, rehabilitation, maternity, and alcoholic or narcotic dependency facilities.

## Hospital-based physician

See Appendix II, Physician.

## Hospital day

See Appendix II, Days of care.

## Hospital utilization

Estimates of hospital utilization (such as hospital discharge rate, days of care rate, average length of stay, and percentage of the population with a hospitalization) presented in Health, United States are based on data from three sources: Healthcare Cost and Utilization Project, National (Nationwide) Inpatient Sample (HCUP-NIS); National Health Interview Survey (NHIS); and American Hospital Association (AHA). Beginning with the 2012 data year, HCUP-NIS is a 20% sample of discharges (alive or deceased) from all community hospitals participating in HCUP, excluding rehabilitation and long-term acute care hospitals. For prior years, HCUP-NIS estimates are based on hospital stays for persons discharged alive or deceased from about 1,000 hospitals sampled to approximate a 20% stratified sample of U.S. community hospitals, excluding rehabilitation hospitals and long-term acute care hospitals. NHIS hospital utilization data are based on household interviews with a sample of the civilian noninstitutionalized population. NHIS respondents were asked whether they had any hospital stays in the past year, excluding overnight stays in the emergency room. AHA data are from information reported by a census of hospitals. (Also see Appendix II, Average length of stay; Days of care; Discharge; and Appendix I, Healthcare Cost and Utilization Project [HCUP], National [Nationwide] Inpatient Sample; National Health Interview Survey [NHIS].)

## Human immunodeficiency virus (HIV) disease

Caused by infection with a cytopathic retrovirus, which in turn leads to destruction of parts of the immune system. A surveillance case for HIV requires laboratory-confirmed evidence of infection, including a positive result on a screening test for HIV antibody, followed by a positive result on a confirmatory test, or a positive result or detectable quantity on an HIV virologic test (see: Centers for Disease Control and Prevention [CDC]. Diagnoses of HIV infection in the United States and dependent areas, 2015. 2016. Available from: https://www.cdc.gov/hiv/pdf/library/reports/surveillance/cdc-hiv-surveillance-report-2015-vol-27.pdf).

Since 1985, many states and U.S. dependent areas have implemented HIV case reporting as part of their comprehensive HIV and AIDS surveillance programs. As of April 2008, all reporting areas (50 states, the District of Columbia, and the 6 U.S. dependent areas of American Samoa, Guam, the Northern Mariana Islands, Puerto Rico, the Republic of Palau, and the U.S. Virgin Islands) had implemented HIV case surveillance using a confidential system for name-based case reporting for both HIV infection and AIDS. To better capture and characterize populations in which HIV infection has been newly diagnosed, including persons with evidence of recent HIV infection, many states report the prevalence of those living with a diagnosis of HIV infection, including those living with AIDS.

In 2008, changes were made to the case definition for HIV infection. The new case definition combined the two previous case definitions for HIV and AIDS and established a new disease staging classification. The term “HIV/AIDS” was replaced with the term “diagnosis of HIV infection,” which is defined as diagnosis of HIV infection regardless of the stage of disease (stage 1, 2, 3 [AIDS], or unknown) and refers to all persons with a diagnosis of HIV infection (see “Revised Surveillance Case Definitions for HIV Infection Among Adults, Adolescents, and Children Aged < 18 Months and for HIV Infection and AIDS Among Children Aged 18 Months to < 13 Years—United States, 2008”).

The 2008 case definition was used to classify cases diagnosed from the beginning of the epidemic through 2013. In order to classify HIV infection among both adults and adolescents, the following HIV infection classification staging system was used:

- HIV infection, stage 1: No AIDS-defining condition and either a CD4 count of 500 cells/μL or more or a CD4 percentage of total lymphocytes of 29% or more
- HIV infection, stage 2: No AIDS-defining condition and either a CD4 count of 200-499 cells/μL or a CD4 percentage of total lymphocytes of 14% to 28%
- HIV infection, stage 3 (AIDS): Documentation of an AIDS-defining condition, or either a CD4 count of less than 200 cells/μL or a CD4 percentage of total lymphocytes of less than 14%; documentation of an AIDS-defining condition supersedes a CD4 count or percentage that would not by itself be the basis for a stage 3 (AIDS) classification
- HIV infection, stage unknown: No reported information on AIDS-defining conditions and no information available on CD4 count or percentage (see “Revised Surveillance Case Definitions for HIV Infection Among Adults, Adolescents, and Children Aged < 18 Months and for HIV Infection and AIDS Among Children Aged 18 Months to < 13 Years—United States, 2008”)

In 2014, the HIV surveillance case definition was revised again to adapt to changes in diagnostic criteria used by laboratories and clinicians (see CDC “HIV Surveillance Report, 2014”). The 2014 case definition was used to classify cases diagnosed beginning in 2014 and is similar to the 2008 case definition except for the following: (a) inclusion of criteria for stage 0, (b) inclusion of CD4 testing criteria for stage 3 in children, and (c) changes in cutoffs for CD4 percentages of total lymphocytes used for classifications of stages 1 and 2 in persons aged 6 years and over. The 2014 case definition classifies HIV infection based on the following stages:

- HIV infection, stage 0: First positive HIV test result within 6 months after negative test result; after 6 months, the stage may be reclassified as 1, 2, 3, or unknown
- HIV infection, stages 1,2, and 3: Documentation of an AIDS-defining condition (excluding stage 0) is stage 3; otherwise, the stage is determined by the lowest CD4 test result
- HIV infection, stage unknown: No reported information on AIDS-defining conditions and no information available on CD4 count or percentage

Mortality coding—Starting with 1999 data and the introduction of the 10th revision of the International Classification of Diseases (ICD-10), the title for this cause of death was changed from HIV infection to HIV disease, and the ICD codes were changed to B20-B24 Starting with 1987 data, the National Center for Health Statistics introduced category numbers *042-*044 for classifying and coding HIV infection as a cause of death in ICD-9. The asterisks before the category numbers indicate that these codes were not part of the original ICD-9. HIV infection was formerly referred to as human T-cell lymphotropic virus-III/lymphadenopathy-associated virus (HTLV-III/LAV) infection. Before 1987, deaths involving HIV infection were classified to “Deficiency of cell-mediated immunity” (ICD-9 code 279.1) contained in the category “All other diseases;” to “Pneumocystosis” (ICD-9 code 136. 3) contained in the category “All other infectious and parasitic diseases;” to “Malignant neoplasms, including neoplasms of lymphatic and hematopoietic tissues;” and to a number of other causes. Because of these coding changes, death statistics for HIV infection before 1987 are not strictly comparable with data for 1987 and subsequent years, and therefore are not shown in Health, United States.

(Also see Appendix II, Acquired immunodeficiency syndrome [AIDS]; Cause of death; International Classification of Diseases [ICD]; International Classification of Diseases, 9th Revision, Clinical Modification [ICD-9-CM]; Table IV.)

## Hypercholesterolemia

See Appendix II, Cholesterol.

## Hypertension

In Health, United States, participants are considered to have hypertension if they have measured high blood pressure or if they report taking a prescription medicine for high blood pressure Measured high blood pressure is a systolic blood pressure of at least 140 mm Hg or diastolic blood pressure of at least 90 mm Hg. An average of up to three systolic and diastolic blood pressure readings were used for systolic and diastolic blood pressure values. For antihypertensive medication use, respondents were asked, “Are you now taking prescribed medicine for your high blood pressure?”

Uncontrolled high blood pressure is defined as having measured high blood pressure, among those with hypertension. Those with uncontrolled high blood pressure may also be taking prescribed medicine for high blood pressure. These blood pressure definitions are consistent with the National Heart, Lung, and Blood Institute’s (NHLBI) “Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure” (available from: https://www.nhlbi.nih.gov/guidelines/hypertension/jnc7full.pdf), and “An Effective Approach to High Blood Pressure Control: A Science Advisory From the American Heart Association, the American College of Cardiology, and the Centers for Disease Control and Prevention” (available from: http://hyper.ahajournals.org/content/63/4/878).

In October 2017, a revised set of practice guidelines from the American College of Cardiology/American Heart Association Task Force was released. These new guidelines set lower cutoff points for defining high blood pressure: average measured systolic blood pressure of at least 130 mm Hg or diastolic pressure of at least 80 mm Hg. These standards capture what NHLBI categorizes as “prehypertension;” however, they have not yet been adopted by NHLBI and other organizations. Therefore, Health, United States continues to use the current standards of systolic blood pressure of at least 140 mm Hg or diastolic pressure of at least 90 mm Hg for hypertension estimates. The impact of the lower blood pressure cutoff points on the percentage of the population that would be classified as having high blood pressure is shown in Table VI. Among adults aged 20 and over, the age-adjusted prevalence of high blood pressure in 2013-2016 would be 14.9% under the current standards and 34.0% under the alternate standards. Applying the alternate standard to the age-adjusted prevalence of high blood pressure in 1999-2002 would change the percentage from 19.9% to 42.9%. Substantial changes in the percentage with high blood pressure were observed among males and females, across racial and ethnic groups, and by age group (Table VI).

For more information on the alternate standards, see: Whelton PK, Carey RM, Aronow WS, Casey Jr DE, Collins KJ, Himmelfarb CD, et al. 2017 ACC/AHA/AAPA/ABC/ACPM/AGS/APhA/ASH/ASPC/NMA/PCNA guideline for the prevention, detection, evaluation, and management of high blood pressure in adults. J Am Coll Cardiol. 2017. Available from: http://hyper.ahajournals.org/content/early/2017/11/10/HYP.0000000000000065.

Blood pressure data presented in Health, United States are from the National Health and Nutrition Examination Survey (NHANES). Blood pressure is measured by averaging up to three blood pressure readings taken for an NHANES participant. Blood pressure readings of 0 mm Hg are not included in the estimates. The methods used to measure the blood pressure of participants have changed over the different NHANES survey years. Changes have included the following:

- Number of blood pressure measurements taken (increased from one to four)
- Equipment maintenance procedures
- Training of persons taking readings (physician, nurse, or interviewer)
- Proportion zero end-digits for systolic and diastolic readings
- Published diastolic definition
- Location where the measurements were taken (mobile examination center [MEC] or home)

In 1999 and subsequent years, blood pressure was measured for participants aged 8 years and over in the NHANES MEC by one of its physicians. Three consecutive blood pressure readings are obtained using the same arm. If a blood pressure measurement was interrupted or incomplete, a fourth attempt may be made. Both systolic and diastolic measurements are recorded to the nearest even number. Participants with any of the following on both arms were excluded from the examination: rashes, gauze dressings, casts, edema, paralysis, tubes, open sores or wounds, withered arms, a-v shunts, or radical mastectomy. Patients were also excluded if the blood pressure cuff did not fit on the arm.

In NHANES III, three sets of blood pressure measurements were taken in the MEC for examinees aged 5 years and over. Blood pressure measurements were also taken by trained interviewers during the household interview, on sample persons aged 17 and over. Systolic and diastolic average blood pressures were computed as the arithmetic mean of six or fewer measurements obtained at the household interview (maximum of three) and the MEC examination (maximum of three). If the examinee did not have blood pressure measurements taken in the MEC, this variable was calculated from measurements taken at the household interview Both systolic and diastolic measurements were recorded to the nearest even number.

For more information on changes in blood pressure measurement in NHANES up to 1991, see: Burt VL, Cutler JA, Higgins M, Horan MJ, Labarthe D, Whelton P, et al. Trends in the prevalence, awareness, treatment, and control of hypertension in the adult U.S. population: Data from the health examination surveys, 1960 to 1991. Hypertension 26(1):60-9 1995

## ICD; ICD codes

See Appendix II, Cause of death; International Classification of Diseases (ICD).

## Illicit drug use

Refers to the use and misuse of illegal and controlled drugs.

Monitoring the Future (MTF) Study—In this school-based survey of secondary school students, information on illicit drug use is collected using self-completed questionnaires. The information is based on the following questions: “On how many occasions (if any) have you used marijuana in the last 30 days?” Similar questions are asked about lifetime and past year use of marijuana and a range of other drugs, including hallucinogens, inhalants, cocaine, and heroin. Questions on cocaine use include the following: “On how many occasions (if any) have you taken crack (cocaine in chunk or rock form) during the last 30 days?” and “On how many occasions (if any) have you taken cocaine in any other form during the last 30 days?” Starting in 2014, the question on MDMA asks, “On how many occasions (if any) have you taken MDMA (ecstasy or Molly) during the past 30 days?” Previously, the question only asked about ecstasy use before Molly—a nickname for a supposedly stronger form of MDMA—became a popular form of the drug. Questions about prescription drugs (tranquilizers, sedatives, narcotic drugs other than heroin, and amphetamines) provide a description of the legitimate uses for those drugs and then ask respondents to include only use “…on your own, that is, without a doctor telling you to take them.”

National Survey on Drug Use and Health (NSDUH)—Information on illicit drug use is collected for survey participants aged 12 and over. Information on any illicit drug use includes any use of marijuana or hashish, cocaine, crack, heroin, hallucinogens, inhalants or methamphetamine, as well as misuse of prescription psychotherapeutic drugs Current use (within the past month) is based on the question: “How long has it been since you last used [drug name]?” This answer is cross-checked with the following question: “Think specifically about the past 30 days, from [DATE] up to and including today. During the past 30 days, on how many days did you use [drug name]?” Starting in 2013, information about marijuana use that was recommended by a doctor or other health care professional has been collected; however, reported marijuana use is classified as illicit drug use. Starting in 2015, the NSDUH questionnaire underwent a partial redesign, and changes in measurement for 7 of the 10 illicit drug categories—hallucinogens, inhalants, methamphetamine, and the misuse of prescription pain relievers, tranquilizers, stimulants, and sedatives—may have affected the comparability of the measurement of these illicit drugs and any illicit drug with earlier years (Also see Appendix II, Substance use.)

## Immunization

See Appendix II, Vaccination.

## Incidence

The number of cases of disease having their onset during a prescribed period of time. It is often expressed as a rate (e.g., the incidence of measles per 1,000 children aged 5-15 years during a specified year). Measuring incidence may be complicated because the population at risk for the disease may change during the period of interest due to births, deaths, or migration, for example. In addition, determining whether a case is new—that is, whether its onset occurred during the prescribed period of time—may be difficult. Because of these difficulties in measuring incidence, many health statistics are instead measured in terms of prevalence. (Also see Appendix II, Prevalence.)

## Income

See Appendix II, Family income.

## Individual practice association (IPA)

See Appendix II, Health maintenance organization (HMO).

## Industry of employment

For the presentation of data in Health, United States, industries are classified according to the North American Industry Classification System (NAICS). NAICS groups establishments into industries based on their production or supply function. Establishments using similar raw material inputs, capital equipment, and labor are classified in the same industry. This approach creates homogeneous categories well suited for economic analysis. NAICS uses a six-digit hierarchical coding system to classify all economic activity. The first two digits of the six-digit code designate the highest level of aggregation into the public administration (government) and 20 private industry sectors (Table IX). Agriculture, forestry, fishing and hunting; mining, quarrying, and oil and gas extraction; construction; and manufacturing are primarily goods-producing sectors, and the remaining 16 sectors are entirely service providing. NAICS allows for the classification of more than 1,000 industries. For more information on NAICS, see: https://www.census.gov/eos/www/naics.

Starting in 1997, NAICS replaced the Standard Industrial Classification (SIC) system, which was last updated in 1987. The SIC system focused on the manufacturing sector of the economy and provided significantly less detail for the now-dominant service sector, including newly developed industries in information services, health care delivery, and high-technology manufacturing. Although some titles in SIC and NAICS are similar, there is little comparability between the two systems because industry groupings are defined differently. Estimates classified by NAICS should not be compared with estimates that used SIC.

## Infant death

The death of a live-born child before his or her first birthday. Age at death may be further classified as neonatal or postneonatal. Neonatal deaths are those that occur before the 28th day of life; postneonatal deaths are those that occur within 28 days to under 1 year of age. (Also see Appendix II, Rate: Death and related rates.)

## Injury

The International Classification of External Causes of Injuries (ICECI) Coordination and Maintenance Group defines injury as a (suspected) bodily lesion resulting from acute overexposure to energy (this can be mechanical, thermal, electrical, chemical, or radiant) interacting with the body in amounts or rates that exceed the threshold of physiological tolerance. The time between exposure to the energy and the appearance of an injury is short. In some cases, an injury results from an insufficiency of any of the vital elements (i.e., air, water, or warmth), as in strangulation, drowning, or freezing. Acute poisonings and toxic effects, including overdoses of substances and wrong substances given or taken in error are included, as are adverse effects and complications of therapeutic, surgical, and medical care. Psychological harm is excluded. Injuries can be intentional or unintentional (i.e., accidental). In National Center for Health Statistics (NCHS) data systems, external causes of nonfatal injuries are currently coded according to the International Classification of Diseases, 9th Revision, Clinical Modification, Supplementary Classification of External Causes of Injury and Poisoning, and the codes are often referred to as E codes. See Table X for a list of external causes-of-injury categories and E codes used in Health, United States. Also see the NCHS injury website at: https://www.cdc.gov/nchs/injury.htm; and see: World Health Organization. International Classification of External Causes of Injuries (ICECI), Version 1.2. 2004. Available from: http://www.who.int/classifications/icd/adaptations/iceci/en/. (Also see Appendix II, Diagnosis; Injury-related visit.)

## Injury-related visit

In the National Hospital Ambulatory Medical Care Survey (NHAMCS), an emergency department visit was considered injury related if the physician diagnosis was injury related or an external cause-of-injury code (E code) was present (Table X). Starting with Health, United States, 2008, an injury-related visit was redefined as an initial injury visit. In the 2001-2010 NHAMCS, an initial injury visit was the first visit to an emergency department for an injury that was characterized by either the first-listed diagnosis being a valid injury diagnosis or by a valid first-listed E code, regardless of the diagnosis code. Visits for which the first-listed diagnosis or the first-listed E code was for a complication of medical care or for an adverse event were not counted as injury visits. For 2001-2004 and 2007 and subsequent data years, the patient record form had a specific question on whether the episode of care was an initial visit for the problem. In the 2005 and 2006 surveys, this variable was not included, and in its place an imputed variable was constructed that indicated whether the visit was or was not the initial visit for the problem. For an explanation of the methodology used to create the imputed initial visit variable, see: https://www.cdc.gov/nchs/data/ahcd/initialvisit.pdf. For more information, see the National Center for Health Statistics Injury Data and Resources website at: https://www.cdc.gov/nchs/injury.htm; and, Fingerhut LA. Recommended definition of initial injury visits to emergency departments for use with the NHAMCS-ED data. NCHS. Health E-Stats. 2006. Available from: https://www.cdc.gov/nchs/data/hestat/injury/injury.htm. (Also see Appendix II, Emergency department or emergency room visit; External cause of injury; Injury.)

## Inpatient

A person who is formally admitted to the inpatient service of a hospital for observation, care, diagnosis, or treatment. (Also see Appendix II, Admission; Average length of stay; Days of care; Discharge; Hospital.)

## Inpatient care

See Appendix II, Hospital utilization.

## Inpatient day

See Appendix II, Days of care.

## Instrumental activities of daily living (IADL)

Activities related to independent living, including preparing meals, managing money, shopping for groceries or personal items, performing light or heavy housework, and using a telephone. In the National Health Interview Survey, respondents are asked whether they or family members need the help of another person for handling routine IADLs because of a physical, mental, or emotional problem.

In the Medicare Current Beneficiary Survey, if a sample person had any difficulty performing an activity by him- or herself and without special equipment or did not perform the activity at all because of health problems, the person was categorized as having a limitation in that activity The limitation may have been temporary or chronic at the time of interview. Sampled persons in the community answered health status and functioning questions themselves, if able to do so. For sampled persons in a long-term care facility, a proxy—such as a nurse—answered questions about the sampled person’s health status and functioning. (Also see Appendix II, Activities of daily living [ADL]; Functional limitation; Limitation of activity.)

## Insurance

See Appendix II, Health insurance coverage.

## Intermediate care facility

See Appendix II, Nursing home.

## International Classification of Diseases (ICD)

Used to code and classify cause-of-death data. ICD is developed collaboratively by the World Health Organization and 10 international centers, 1 of which is housed at the National Center for Health Statistics (NCHS). The purpose of ICD is to promote international comparability in the collection, classification, processing, and presentation of health statistics. Since 1900, ICD has been modified about once every 10 years, except for the 20-year interval between the 9th and 10th revisions (ICD-9 and ICD-10) (Table III). The purpose of the revisions is to stay abreast of advances in medical science. New revisions usually introduce major disruptions in time series of mortality statistics (Tables IV and V). For more information, see the NCHS ICD-10 website at: https://www.cdc.gov/nchs/icd/icd10.htm. (Also see Appendix II, Cause of death; Comparability ratio; International Classification of Diseases, 9th Revision, Clinical Modification [ICD-9-CM].)

Table IX Codes for industries, based on the North American Industry Classification System (NAICS)

Industry | Code
Agriculture, forestry, fishing and hunting | 11
Mining, quarrying, and oil and gas extraction | 21
Utilities | 22
Construction | 23
Manufacturing | 31-33
Wholesale trade | 42
Retail trade | 44-45
Transportation and warehousing | 48-49
Information | 51
Finance and insurance | 52
Real estate and rental and leasing | 53
Professional, scientific, and technical services | 54
Management of companies and enterprises | 55
Administrative and support and waste management and remediation services | 56
Educational services | 61
Health care and social assistance | 62
Arts, entertainment, and recreation | 71
Accommodation and food services | 72
Other services, except public administration | 81
Public administration | 92

SOURCE: Bureau of Labor Statistics. Available from: https://www.census.gov/eos/www/naics/.

## International Classification of Diseases, 9th Revision, Clinical Modification (ICD-9-CM)

Based on, and compatible with, the World Health Organization’s ICD-9. The United States used ICD-9-CM to code morbidity diagnoses and inpatient procedures until October 1, 2015, when the International Classification of Diseases, 10th Revision, Clinical Modification/Procedure Coding System (ICD-10-CM/PCS) went into effect. ICD-9-CM consists of three volumes. Volumes 1 and 2 contain the diagnosis tabular list and index; Volume 3 contains the procedure classification (tabular list and index combined).

ICD-9-CM is divided into 17 chapters and 2 supplemental classifications. The chapters are arranged primarily by body system. In addition, there are chapters for Infectious and parasitic diseases; Neoplasms; Endocrine, nutritional, and metabolic diseases; Mental disorders; Complications of pregnancy, childbirth, and puerperium; Certain conditions originating in the perinatal period; Congenital anomalies; and Symptoms, signs, and ill-defined conditions. The two supplemental classifications are for factors influencing health status and contact with health services (V codes), and for external causes of injury and poisoning (E codes).

Table X Codes for external causes of injury, from the International Classification of Diseases, 9th Revision, Clinical Modification

External cause-of-injury category | E code
All injury | E800-E869, E880-E929, E950-E999
Unintentional | E800-E869, E880-E929
Motor-vehicle traffic | E810-E819
Falls | E880-E886, E888
Struck by or against objects or persons | E916-E917
Caused by cutting and piercing instruments or objects | E920
Intentional (suicide and homicide) | E950-E969, E979, E999.1
Undetermined | E980-E989
Other (includes legal intervention and operations of war) | E970-E978, E990-E999.0

SOURCE: CDC. Recommended framework of E code groupings for presenting injury morbidity data (August 10, 2011). Available from: https://www.cdc.gov/injury/wisqars/ecode_matrix.html; International Classification of Diseases, 9th Revision, Clinical Modification. Available from: https://www.cdc.gov/nchs/icd/icd9cm.htm.

In Health, United States, morbidity data will be classified using ICD-9-CM until 2016 data are available, and then morbidity data will be classified using ICD-10-CM/PCS. ICD-9-CM procedure categories and codes are shown in Table XI. For more information about ICD-9-CM, see the National Center for Health Statistics “Classification of Diseases, Functioning, and Disability” website at: https://www.cdc.gov/nchs/icd.htm. (Also see Appendix II, International Classification of Diseases [ICD]; International Classification of Diseases, 10th Revision, Clinical Modification/Procedure Coding System [ICD-10-CM/PCS].)

## International Classification of Diseases, 10th Revision, Clinical Modification/Procedure Coding System (ICD-10-CM/PCS)

Use of ICD-10-CM/PCS to report medical diagnoses and inpatient procedures was implemented October 1, 2015. The transition to ICD-10 is required for everyone covered by the Health Insurance Portability and Accountability Act. This change to ICD-10 does not affect Current Procedural Terminology coding for outpatient procedures and physician services. ICD-10-CM/PCS consists of two parts: ICD-10-CM for diagnosis coding, and ICD-10-PCS for inpatient procedure coding. For more information about ICD-10-CM/PCS, see the National Center for Health Statistics “Classification of Diseases, Functioning, and Disability” website at: https://www.cdc.gov/nchs/icd.htm; and the Centers for Medicare & Medicaid Services’ ICD-10 transition website at: https://www.cms.gov/Medicare/Coding/ICD10/index.html.

## Late fetal death rate

See Appendix II, Rate: Death and related rates.

## Leading causes of death

See Appendix II, Cause-of-death ranking Length of stay—See Appendix II, Average length of stay.

## Life expectancy

The average number of years of life remaining to a person at a particular age and based on a given set of age-specific death rates—generally the mortality conditions existing in the period mentioned. Life expectancy may be determined by sex, race and Hispanic origin, or other characteristics, by using age-specific death rates for the population with that characteristic (Also see Appendix II, Rate: Death and related rates.)

U.S. life tables by Hispanic origin were available starting with 2006 data. Life expectancy data for the Hispanic population were not available before 2006 for three major reasons: (a) coverage of the Hispanic population in the U.S. mortality statistics system was incomplete, (b) misclassification of Hispanic persons on death certificate data underestimated deaths in the Hispanic population, and (c) misstatement of age at the oldest ages in the Hispanic population led to an underestimation of mortality at the oldest ages.

Hispanic origin was added to the U.S. standard death certificate in 1989, but it was not adopted by every state until 1997. By 1997, all states had reporting rates over 99%. Research on race and Hispanic-origin reporting on U.S. death certificates found that misclassification of race and Hispanic origin accounts for a net underestimate of 5% for total Hispanic deaths, 1% for total non-Hispanic black deaths, and 0.5% for non-Hispanic white deaths. To address the effects of age misstatement at the oldest ages, the probability of death for Hispanic persons over age 80 is estimated as a function of non-Hispanic white mortality with the use of the Brass relational-logit model. For more information, see: Arias E. United States life tables by Hispanic origin. National Center for Health Statistics. Vital Health Stat 2(152). 2010. Available from: https://www.cdc.gov/nchs/data/series/sr_02/sr02_152.pdf.

Life tables are used in the calculation of life expectancy and have been available since 1945. From 1945 through 1996, the annual life tables were abridged life tables, closed at age 85 and over, and were constructed by reference to a standard table. Beginning with 1997 mortality data, a new methodology similar to that of the 1989-1991 decennial life tables was employed to estimate annual complete life tables to age 100, with combined life table values presented for ages 100 and over. The methodology was again revised for 2000-2007 using a methodology similar to that of the 1999-2001 decennial life tables. Beginning with 2008 data, the life table methodology was refined by changing the smoothing technique used to estimate the life table functions at the oldest ages. All intercensal life tables (2001-2009) were revised with the new methodology and the intercensal population estimates. As a result, data post-2000 may differ from figures published previously. For a full description of the 2008 life table methodology, see: Arias E. United States life tables, 2008. National Vital Statistics Reports; vol 61 no 3. Hyattsville, MD: National Center for Health Statistics. 2012. Available from: https://www.cdc.gov/nchs/data/nvsr/nvsr61/nvsr61_03.pdf. Starting with Health, United States, 2016, life expectancy estimates for 2010 and beyond were revised to reflect updated race and Hispanic-origin classification ratios. See: Arias E, Heron M, Hakes JK. The validity of race and Hispanic-origin reporting on death certificates in the United States: An update. National Center for Health Statistics. Vital Health Stat 2(172). 2016. Available from: https://www.cdc.gov/nchs/data/series/sr_02/sr02_172.pdf. Additional life table estimates are available from the life tables website at: https://www.cdc.gov/nchs/products/life_tables.htm.

Table XI Codes for procedure categories for Healthcare Cost and Utilization Project data, from the International Classification of Diseases, 9th Revision, Clinical Modification

Procedure category | Code
Amputation of lower extremity (amputation of lower limb) | 84.10-84.19
Appendectomy | 47.0, 47.01, 47.09, 47.1, 47.11, 47.19
Arthroplasty knee (knee replacement) | 00.80-00.84, 81.41-81.44, 81.46, 81.47, 81.54, 81.55
Cesarean section | 74.0,74.1,74.2, 74.4, 74.99
Cholecystectomy (gall bladder removal) | 51.21-51.24, 51.41-51.43, 51.49, 51.51, 51.59
Colorectal resection (removal of part of the bowel) | 17.31-17.36, 17.39, 45.71-45.76, 45.79, 45.8, 45.81-45.83, 48.40-48.43, 48.49, 48.5, 48.50-48.52, 48.59, 48.61-48.66, 48.69
Coronary artery bypass graft (CABG) | 36.10-36.17, 36.19, 36.2, 36.3, 36.31-36.34, 36.39
Endarterectomy (plaque removal from artery lining of brain, head, neck) | 38.11,38.12
Heart valve procedures | 35.00-35.14, 35.20-35.28, 35.96, 35.97, 35.99
Hip replacement | 00.70-00.77, 00.85-00.87, 81.51-81.53, 81.69
Hysterectomy | 68.3, 68.31, 68.39, 68.4, 68.41, 68.49, 68.5, 68.51, 68.59, 68.6, 68.61, 68.69, 68.7, 68.71, 68.79, 68.9
Incision and excision of central nervous system (brain surgery) | 01.01, 01.09, 01.21-01.28, 01.31, 01.32, 01.39, 01.41, 01.42, 01.51-01.53,01.59
Insertion, revision, replacement, removal of cardiac pacemaker | 00.50-00.54, 00.56, 00.57, 17.51, 17.52, 37.70-37.83, 37.85-37.87, 37.89, 37.94-37.98
Laminectomy (spine surgery) | 03.02, 03.09, 80.5, 80.50, 80.51, 80.59, 84.59-84.69, 84.80-84.85,
Ligation of fallopian tubes ("tying" of fallopian tubes) | 66.21, 66.22, 66.29, 66.31, 66.32, 66.39
Oophorectomy (removal of one or both ovaries) | 65.3, 65.31, 65.39, 65.4, 65.41, 65.49, 65.51-65.54, 65.61-65.64
Percutaneous coronary angioplasty (PTCA) (balloon angioplasty) | 00.66, 17.55, 36.01, 36.02, 36.05
Small bowel resection (removal of part of the small bowel) | 45.61-45.63
Spinal fusion | 81.00-81.09, 81.30-81.39, 81.61-81.64, 84.51
Tonsillectomy or adenoidectomy | 28.2, 28.3, 28.6, 28.7
Treatment, fracture or dislocation of hip and femur | 78.55, 78.65, 79.05, 79.15, 79.25, 79.35, 79.45, 79.55, 79.65, 79.75, 79.85, 79.95

NOTES: Procedures were classified by the Clinical Classifications Software (CCS). For more information, see: https://www.hcup-us.ahrq.gov/toolssoftware/ccs/AppendixBSinglePR.txt.

SOURCE: Agency for Healthcare Research and Quality.

## Limitation of activity

May be defined in different ways, depending on the conceptual framework. In the National Health Interview Survey, limitation of activity refers to a long-term reduction in a person’s capacity to perform the usual kind or amount of activities associated with his or her age group as a result of a chronic condition. Limitation of activity is assessed by asking persons a series of questions about limitations in their or a family member’s ability to perform activities usual for their age group because of a physical, mental, or emotional problem. Persons are asked about limitations in activities of daily living, instrumental activities of daily living, play, school, work, difficulty walking or remembering, and any other activity limitations. For reported limitations, the causal health conditions are determined, and persons are considered limited if one or more of these conditions is chronic. Children under age 18 who receive special education or early intervention services are considered to have a limitation of activity. (Also see Appendix II, Activities of daily living [ADL]; Instrumental activities of daily living [IADL].)

## Long-term care facility

A residence that provides a specific level of personal or medical care or supervision to residents. In the Medicare Current Beneficiary Survey, a residence is considered a long-term care facility if it has three or more long-term care beds and answers affirmatively to at least one of three questions: “Does this facility (a) provide personal care services to residents, (b) provide continuous supervision of residents, or (c) provide any long-term care?” Types of long-term care facilities include licensed nursing homes, skilled nursing homes, intermediate care facilities, retirement homes (that provide services), domiciliary or personal care facilities, distinct long-term care units in a hospital complex, mental health facilities and centers, assisted and foster care homes, assisted living facilities, and institutions for persons with intellectual disabilities (formerly called mentally retarded) and the developmentally disabled. (Also see Appendix II, Nursing home.)

## Low birthweight

See Appendix II, Birthweight.

## Mammography

An x-ray image of the breast used to detect irregularities in breast tissue. In the National Health Interview Survey (NHIS), questions concerning use of mammography are asked on an intermittent schedule, and question content has differed across years. Mammograms may be used for diagnostic or screening purposes, but the purpose cannot be determined from NHIS.

In Health, United States, use of mammography was defined as “percent of women having a mammogram within the past two years.” Survey questions have changed over time.

In 1987 and 1990, women were asked to report the number of days, weeks, months, or years that had passed since their most recent mammogram. In 1991, women were asked whether they had a mammogram in the past 2 years. In 1993 and 1994, women were asked whether they had a mammogram within the past year, between 1 to 2 years ago, or more than 2 years ago. In 1998, women were asked whether they had a mammogram a year ago or less, more than 1 year but not more than 2 years, more than 2 years ago but not more than 3 years, more than 3 years but not more than 5 years, or more than 5 years ago.

In 1999, women were asked to report the number of days, weeks, months, or years that had passed since their most recent mammogram. Estimates for 1999 may be slightly overestimated in comparison with previous years: women who responded “2 years ago” (10% of women) may include those who received a mammogram more than 2 years but less than 3 years ago.

In 2000 and 2003, women were asked when they had their most recent mammogram (asked to give month and year). Women who did not respond were given a follow-up question that used the 1999 wording, and women who did not respond to the 1999 wording were asked a second follow-up question that used the 1998 wording. Estimates for 2000 and 2003 may be slightly overestimated in comparison with estimates prior to 1999: women who responded “2 years ago” (2% of women) may include those who received a mammogram more than 2 years but less than 3 years ago.

In 2005, women were asked the same series of mammography questions as in the 2000 and 2003 surveys, but the questionnaire skip pattern was modified so that more women were asked the follow-up question using the 1998 wording. Thus, estimates for 2005 and subsequent years are more precise than estimates for 1999, 2000, and 2003. SAS code to categorize mammography data for 2000 and beyond is available from: https://www.cdc.gov/nchs/nhis/nhis_2005_data_release.htm. In 2008, 2010, 2013, and 2015, the mammography questions were identical to those asked in 2005

The recommended age to begin mammography screening and the interval between screenings has changed over time. The current recommendation, made by the U.S. Preventive Services Task Force in 2016, is the use of screening mammography for breast cancer every 2 years in women aged 50-74, with additional guidance provided for women aged 40-49. For additional information, see: U.S. Preventive Services Task Force. Breast cancer: Screening. 2016. Available from: https://www.uspreventiveservicestaskforce.org/Page/Document/RecommendationStatementFinal/breast-cancer-screening1; and U.S. Preventive Services Task Force. The guide to clinical preventive services, 2014. 2014. Available from: https://www.ahrq.gov/sites/default/files/wysiwyg/professionals/clinicians-providers/guidelines-recommendations/guide/cpsguide.pdf.

## Managed care

A term originally used to refer to prepaid health plans (generally, health maintenance organizations, or HMOs) that furnish care through a network of providers under a fixed budget and “manage” costs. Increasingly, the term is also used to include preferred provider organizations (PPOs) and even forms of indemnity insurance coverage (i.e., fee-for-service insurance).

Medicare managed care includes a combination of risk- and cost-based plans. Risk-based plans receive a fixed prepayment per beneficiary per month to help pay for the cost of all covered services that a beneficiary may use. Each year, the Centers for Medicare & Medicaid Services (CMS) announces a “benchmark” amount for each county for coverage of Medicare Part A and Part B services. A managed care plan contracting with Medicare then submits a “bid,” which represents the revenue it needs to cover these services. If the bid is above the benchmark, the difference must be charged in a premium to the enrollees of the plan. If the bid is below the benchmark, then a portion of the difference must be used to provide additional benefits to enrollees, with the Medicare trust funds receiving the remaining share. The term Medicare Advantage is used to refer to managed care plans, including HMOs, PPOs, private fee-for-service plans, special needs plans, Medicare medical savings account plans, and certain other types of plans.

Cost-based plans are offered by an HMO or a competitive medical plan and are paid for their “reasonable costs” in providing Medicare services to enrollees, based on annual cost reports filed with CMS. For current definitions of the various Medicare managed care plans, see Chapter 1, section 30 (“Other MA Plans”) in the CMS “Medicare Managed Care Manual,” available from: https://www.cms.gov/Regulations-and-Guidance/Guidance/Manuals/Downloads/mc86c01.pdf.

Medicare enrollees can choose to enroll in a managed care program (if available) or to receive services on a fee-for-service basis.

The two major Medicaid managed care categories are risk-based plans (such as managed care organizations [MCOs], prepaid inpatient health plans, and prepaid ambulatory health plans) and primary care case management (PCCM) arrangements. Risk-based plans are paid a fixed fee per enrollee, which is generally paid on a monthly basis. Risk-based plans assume some or all of the financial risk for providing the services covered under the contract. PCCM providers are usually physicians, physician group practices, or entities employing or having other arrangements with such physicians, but they can also include nurse practitioners, nurse midwives, or physician assistants. These providers contract directly with the state to locate, coordinate, and monitor covered primary care (and sometimes additional services). PCCM providers are paid a per-patient case management fee and usually do not assume financial risk for the provision of services. Some states allow Medicaid enrollees to voluntarily enroll in managed care plans; most states require that at least certain categories of Medicaid beneficiaries join such plans. Both risk-based plans and PCCM arrangements include plans that provide specialized services to certain categories of Medicaid beneficiaries. For more information on state Medicaid managed care plans, see https://www.medicaid.gov/.

(Also see Appendix II, Health maintenance organization [HMO]; Medicare; Medicaid; Preferred provider organization [PPO].)

## Marital status

Classified through self-reporting in the categories married and unmarried. The term “married” encompasses all married people, including those separated from their spouses. “Unmarried” includes those who are single (never married), divorced, or widowed.

Birth file—In 1970, 39 states and the District of Columbia (D.C.), and in 1975, 38 states and D.C., included a direct question about mother’s marital status on the birth certificate. Since 1980, national estimates of births to unmarried women have been based on two methods for determining marital status: a direct question in the birth registration process and inferential procedures. For 1980-1996, marital status was reported on the birth certificates of 41 to 45 states and D.C.; with the addition of California in 1997, 46 states and D.C.; and for 1998-2001, 48 states and D.C. In 1997, all but four states (Connecticut, Michigan, Nevada, and New York), and in 1998, all but two states (Michigan and New York) included a direct question about mother’s marital status on their birth certificates. For 1998-2007, marital status was imputed as married on birth records with missing information in the 48 states and D.C. where this information was obtained by a direct question. For 2008-2016 for 49 states and D.C., marital status is reported in the birth registration process. Marital status is imputed if missing on the birth certificate; for 2014-2016 mother’s marital status was imputed for less than 0.1% of birth records in the reporting areas.

For states lacking a direct question, marital status was inferred. Before 1980, the incidence of births to unmarried women in states with no direct question on marital status was assumed to be the same as the incidence in reporting states in the same geographic division. Starting in 1980, for states without a direct question, marital status was inferred by comparing the parents’ and child’s surnames. For 1994-1996, birth certificates in 45 states and D.C. included a question about the mother’s marital status. Beginning in 1997, the marital status of women giving birth in California and Nevada has been determined by a direct question in the birth registration process. Beginning on June 15, 1998, Connecticut discontinued inferring the mother’s marital status and added a direct question regarding mother’s marital status to the state’s birth certificate.

In 2005, Michigan added a direct question to the birth registration process, but it uses inferential procedures to update information collected using the direct question. In both Michigan and New York, a birth is inferred as nonmarital if either of these factors, listed in priority-of-use order, is present: (a) a paternity acknowledgment was received or (b) the father’s name is missing. For 2006-2008 data, inferential procedures were used to compile birth statistics by marital status, in full or in part, for New York and Michigan, respectively. For 2009-2016, mother’s marital status is inferred for New York birth records where it was missing.

National Health Interview Survey (NHIS)—In NHIS, marital status is asked of, or about, all persons aged 14 and over. Respondents are asked, “Are you now married, widowed, divorced, separated, never married, or living with a partner?” In tables, these responses are categorized into three groups: married; divorced, separated, widowed; and never married.

## Maternal age

See Appendix II, Age.

## Medicaid

Authorized in 1965 and became Title XIX of the Social Security Act. Medicaid is a jointly funded cooperative venture between the federal and state governments to assist states in the provision of adequate medical care to eligible persons. Within broad federal guidelines, each state establishes its own eligibility standards; determines the type, amount, duration, and scope of services; sets the rate of payment for services; and administers its own program.

Medicaid is the largest program providing medical and health-related services to low-income individuals. Medicaid was originally available only to individuals receiving cash assistance, but over time, Congress has expanded eligibility for children and selected adult groups. Most recently, the Affordable Care Act (ACA) and the Health Care and Education Reconciliation Act (HCERA) initiated significant changes to Medicaid. (Subsequent references to ACA in this text will include changes enacted by either ACA or HCERA.)

States are mandated by federal law to cover certain population groups (mandatory eligibility groups) but are granted flexibility in covering other groups (optional eligibility groups). In the standard benefit package, states must cover mandatory benefits (e.g., physician services) but may choose to cover optional benefits (e.g., tuberculosis-related services). Prior to ACA, many states expanded Medicaid coverage above the federal minimums, and many states have chosen to continue this additional coverage. The major coverage change introduced by ACA was to create a new eligibility group—Medicaid expansion to Low-Income Adults—for those with incomes not exceeding 138% of the federal poverty level (FPL) (133% by statute with an additional 5% income disregard). This group is discussed in more detail below.

States set individual eligibility criteria within federal minimum standards. In addition to Medicaid’s financial eligibility requirements, individuals must satisfy federal and state requirements regarding residency, immigration status, and documentation of U.S. citizenship. ACA provided a standard application—available through the Medicaid program or through the Health Insurance Marketplace—and a standard method for calculating income eligibility for Medicaid, the Children’s Health Insurance Program (CHIP), and insurance affordability programs offered through the marketplace, based primarily on modified adjusted gross income (MAGI). Effective 2014, MAGI is used to determine Medicaid and CHIP eligibility for most nondisabled children and adults under age 65.

Broadly, there are four major eligibility groups covered by most states: Children, Adults with Disabilities, Aged Adults, and Nondisabled Adults. These are discussed in more detail below.

Major eligibility groups

Children—Medicaid was originally available only to individuals receiving cash assistance, but Congress has since expanded eligibility for children and other populations, making individuals eligible based on income below a specified percentage of the FPL. ACA raised the minimum Medicaid eligibility for nondisabled children not exceeding 138% FPL (133% by statute with an additional 5% income disregard). Other eligible child groups include: infants born to women covered by Medicaid (known as “deemed newborns”), certain children in foster care or adoption assistance programs, certain children with disabilities, and children who use long-term services and supports. Like disabled adults, most states automatically qualify disabled children in the Supplemental Security Income (SSI) program for Medicaid coverage; eligibility is not determined by the newly introduced MAGI. Some states use more restrictive criteria to determine Medicaid eligibility of children with SSI. These criteria are usually based on income relative to the FPL and assets. Regardless of how they qualify, all children enrolled in Medicaid are entitled to the comprehensive set of health care services known as Early, Periodic Screening, Diagnostic and Treatment. These services include screening for and treatment of any vision or hearing problems, coverage for eyeglasses and hearing aids, and regular preventive dental care and treatment.

Adults with Disabilities—Adults with disabilities from physical conditions, intellectual or developmental disabilities, serious behavioral disorders, or serious mental illness may be eligible for Medicaid. The SSI program pays benefits to disabled adults and children who have limited income and resources. Enrollment in SSI (or the Social Security Disability Insurance program, which provides Medicare to qualified individuals after a 24-month waiting period) automatically qualifies adults with disabilities for Medicaid in most states. However, some states use more restrictive criteria (known as 209(b) of the 1972 amendments to the Social Security Act) to determine Medicaid eligibility. These criteria are often based on income relative to the FPL and assets. As of December 2016, 10 states used more restrictive criteria than enrollment in SSI. Individuals with disabilities who are eligible for Medicaid are entitled to all services that are deemed medically necessary.

All states have the option of covering additional people with low incomes or high medical expenses through other eligibility pathways. These may include covering those at higher income levels; permitting persons with disabilities and high medical expenses to spend down until they are eligible for coverage; setting a special income level to cover institutionalized individuals with incomes up to 300% of the SSI benefit rate; extending coverage to individuals who receive home- and community-based waiver services as an alternative to institutionalization; permitting working individuals who are severely impaired but whose earnings would otherwise disqualify them from Medicaid to buy into Medicaid; or covering adults with disabilities who use long-term services and supports based on their functional status (known as level-of-care) and use of services (e.g., residence in a nursing facility, intermediate care facility for persons with intellectual disabilities, or mental health facility, or requiring significant home-based services).

Aged Adults—The SSI program covers those with disabilities and people aged 65 and over without disabilities who meet the financial limits. In most states, SSI enrollment automatically qualified those aged 65 and over for Medicaid. However, some states use more restrictive criteria (known as 209(b)) to determine Medicaid eligibility. The more restrictive criteria may consider income and assets, disability, or both. Most Medicaid enrollees aged 65 and over are also Medicare beneficiaries. Members of this group are known as dual-eligible beneficiaries. Dual eligibles are eligible for the same Medicare benefits as other Medicare beneficiaries but have low incomes that make it difficult to afford the premiums and cost sharing required by Medicare, as well as the cost of services not covered by the Medicare program (e.g., long-term services and supports). Dual eligibles may qualify for partial Medicaid benefits (to cover Medicare premium and cost sharing) or full Medicaid benefits, in which case they get coverage for the full range of services offered by their state’s Medicaid program.

Like coverage for adults with disabilities, states may extend Medicaid coverage to adults with low incomes or high medical expenses through other eligibility pathways, such as covering those with higher income levels or those with chronic conditions or low functional status requiring institutionalization or significant home-based services. There is considerable variation across states in the optional Medicaid services covered, which results in different benefits for dual-eligible beneficiaries depending on where they live.

Nondisabled Adults—Prior to the enactment of ACA, most low-income nondisabled adults were not eligible for Medicaid unless they were in special groups (e.g., pregnant women, low-income parents, or other caretaker relatives with dependent children) or in states with demonstration programs that provided expanded coverage.

The major eligibility groups of nondisabled adults include the following: Medicaid Expansion to Low-income Adults (the new adult group), Pregnant Women, Parents and Caretaker Relatives, and Adults without Dependent Children. These groups and some specialty eligible groups—Breast and Cervical Cancer Prevention and Treatment Program and Tuberculosis (TB)—are discussed below.

Medicaid Expansion to Low-income Adults—As of October 2016, 31 states and the District of Columbia (D.C.) had chosen to expand their Medicaid programs. These states include: Alaska, Arizona, Arkansas, California, Colorado, Connecticut, Delaware, Hawaii, Illinois, Indiana, Iowa, Kentucky, Louisiana, Maryland, Massachusetts, Michigan, Minnesota, Montana, Nevada, New Hampshire, New Jersey, New Mexico, New York, North Dakota, Ohio, Oregon, Pennsylvania, Rhode Island, Vermont, Washington, and West Virginia.

Pregnant Women—Since 1989, Congress has required Medicaid to cover pregnant women with low income. Currently, all but four states have extended Medicaid coverage to pregnant women above the currently required level of 138% FPL. Maternity-related services covered by the programs include prenatal care, labor and delivery, and 60 days of postpartum care. In Medicaid-expansion states, women at or below 138% FPL who are pregnant when they apply for Medicaid are not eligible for the new adult group. Medicaid coverage as a pregnant woman ends 2 months postpartum (after which the individual may be eligible in another Medicaid eligibility group).

Parents and Caretaker Relatives—Parents and caretaker relatives in low-income families with dependent children are eligible for coverage if their income meets the minimum eligibility levels established in 1996 for financial and medical assistance, which averages 41% of poverty level; 1996 was the year of enactment for welfare reform, which held in place guaranteed Medicaid eligibility for those receiving cash benefits at that time. States have the option to be more or less restrictive than the 1996 standards.

Adults without Dependent Children—Prior to ACA, about one-half of states provided some coverage, through Medicaid demonstration projects or state-funded programs, for nondisabled adults who had limited incomes but did not otherwise qualify for Medicaid. Currently, 31 states and D.C. have implemented ACA Medicaid expansion for adults with incomes at or below 133% of the poverty line (with a 5% income disregard, so effectively 138%).

Other eligibility groups

Breast and Cervical Cancer Prevention and Treatment Program—In 2000, Congress passed the Breast and Cervical Cancer Prevention and Treatment Act, which allowed states to offer eligible women, who were diagnosed with cancer through the Centers for Disease Control and Prevention (CDC)-funded screening program, access to treatment through Medicaid. All states and D.C. have chosen to provide this coverage. For a woman to be eligible under this option, she must be under age 65; have been screened through CDC’s National Breast and Cervical Cancer Early Detection Program; be diagnosed with either breast or cervical cancer, including precancerous conditions; need treatment for breast or cervical cancer; and be uninsured and otherwise not eligible for Medicaid.

Tuberculosis (TB)—States can choose to provide Medicaid coverage of TB-related services for low-income individuals who are infected with TB. This eligibility group serves individuals who are not otherwise eligible for Medicaid based on the traditional eligibility categories.

Medicaid operates as a vendor payment program. States may pay health care providers directly on a fee-for-service basis, or states may pay for Medicaid services through various prepayment arrangements, such as through Medicaid managed care organizations or other forms of managed care. Within federally imposed upper limits and restrictions, each state generally has broad discretion in determining both the payment method and rate for services. Thus, the Medicaid program varies considerably from state to state, as well as within each state over time. For more information, see: https://www.medicaid.gov/ and https://www.macpac.gov.

(Also see Appendix II, Children’s Health Insurance Program [CHIP]; Health expenditures, national; Health insurance coverage; Health maintenance organization [HMO]; Managed care; and Appendix I, Medicaid Statistical Information System [MSIS].)

## Medicaid payments

Under the Medicaid program, medical vendor payments are payments (expenditures) to medical vendors from the state through a fiscal agent or to a health insurance plan. Adjustments are made for cost settlements, third-party recoupments, refunds, voided checks, and financial settlements that cannot be related to specific provided claims. Medicaid medical vendor payments presented in Health, United States do not include payments made to providers from other federal programs or from third-party payers for Medicaid-eligible individuals; payments made from state medical assistance funds that are not federally matchable; cost sharing or enrollment fees collected from recipients or a third party; and administration and training costs Medicaid payment data presented in Health, United States are from the Medical Statistical Information System, which obtains payment data from electronic Medicaid data submitted to the Centers for Medicare & Medicaid Services by each state. Payment data are based on adjudicated claims for medical services reimbursed with Title XIX funds.

## Medical specialty

See Appendix II, Physician specialty.

## Medicare

A nationwide program providing health insurance coverage to selected groups, regardless of income. The covered groups are (a) most people aged 65 and over; (b) people entitled to Social Security or Railroad Retirement disability benefits for at least 24 months (with the waiting period waived or reduced in certain situations); (c) government employees or spouses with Medicare-only coverage who have been disabled for more than 29 months (with the waiting period waived or reduced in certain situations); (d) most people with end-stage renal disease; and (e) certain people in the Libby, Montana, vicinity who are diagnosed with asbestos-related conditions. The program was enacted on July 30, 1965, as Title XVIII of the Social Security Act, “Health Insurance for the Aged and Disabled,” and became effective on July 1, 1966.

From its inception, Medicare has included two separate but coordinated programs: Hospital Insurance (Part A) and Supplementary Medical Insurance (Part B). Part C (Medicare Advantage) was established by the Balanced Budget Act of 1997 (originally as Medicare+Choice) as an expanded set of options for the delivery of health care under Medicare. Although all Medicare beneficiaries can receive their benefits through the original fee-for-service program, most beneficiaries enrolled in both Part A and Part B have the option to participate in a Medicare Advantage plan instead.

Organizations that seek to contract as Medicare Advantage plans must meet specific organizational, financial, and other requirements. Although most Medicare Advantage enrollees are in coordinated care plans, such as health maintenance organizations and preferred provider organizations, Medicare Advantage plans also include private fee-for-service plans, provider-sponsored organizations, special needs plans, medical savings account plans (which provide benefits after a single high deductible is met), and certain other types of plans. Medicare Advantage plans are generally paid on a capitation basis—that is, plans are paid a predetermined amount per member per month, which is adjusted according to the health status of the plans’ members—and are required to provide at least those services covered by Parts A and B, except hospice services. Plans may (and in certain situations must) provide extra benefits (such as vision or hearing coverage) or reduce cost sharing or premiums.

The Medicare Prescription Drug, Improvement, and Modernization Act (also called the Medicare Modernization Act, or MMA) was passed on December 8, 2003. MMA (Pub. L. 108-173) established a voluntary prescription drug benefit for Medicare beneficiaries and created a new Medicare Part D. People eligible for Medicare could begin to enroll in Part D beginning in January 2006. For more information on Medicare, see: https://www.medicare.gov/Pubs/pdf/10050-Medicare-and-you.pdf and https://www.cms.gov/Research-Statistics-Data-and-Systems/Statistics-Trends-and-Reports/CMSProgramStatistics/index.html. (Also see Appendix II, Fee-for-service health insurance; Health insurance coverage; Health maintenance organization [HMO]; Managed care; and Appendix I, Medicare Administrative Data.)

## Metropolitan statistical area (MSA)

The Office of Management and Budget (OMB) defines MSAs according to published standards that are applied to U.S. Census Bureau data. The standards are revised periodically, generally prior to the decennial census, and are applied to the census data to delineate the statistical areas. Revisions to the areas are implemented between censuses by using updated population estimates. The most recent standards were released in June 2010 (available from: https://www.whitehouse.gov/sites/whitehouse.gov/files/omb/bulletins/2013/b13-01.pdf). In August 2017, OMB released a new delineation of the country’s metropolitan and micropolitan statistical areas based on the 2010 standards (available from: https://www.whitehouse.gov/sites/whitehouse.gov/files/omb/bulletins/2017/b-17-01.pdf). New MSA delineations are incorporated into individual data systems at different times.

In the 2000 and 2010 standards, an MSA is a county, or group of contiguous counties, that contains at least one urbanized area with a population of 50,000 or more. In addition to the county or counties that contain all or part of the urbanized area, an MSA may contain other counties if there are strong social and economic ties with the central county or counties, as measured by commuting. Counties that are not within an MSA are considered to be nonmetropolitan. For more information, see: https://www.census.gov/programs-surveys/metro-micro.html. Starting with 2016, most data by MSA currently in Health, United States are based on the June 2013 OMB definitions (2010 OMB standards applied to 2010 Census data). (Also see Appendix II, Urbanization.)

National Health Interview Survey (NHIS)—For respondents to NHIS, designation of place of residence as metropolitan or nonmetropolitan is based on the following MSA definitions: for 2016 and beyond, based on the June 2013 OMB definitions (2010 OMB standards applied to 2010 Census data); for 2006-2015, based on the June 2003 OMB definitions (2000 OMB standards applied to 2000 Census data); for 1995-2005, based on the June 1993 OMB definitions (1990 OMB standards applied to 1990 Census data); and for 1985-1994, based on the June 1983 OMB definitions (1980 OMB standards applied to 1980 Census data). For estimates based on 2016 NHIS data combined with earlier years of NHIS, metropolitan status of residence for all years involved is based on the June 2013 definitions. Introduction of each set of standards may create a discontinuity in trends.

National Immunization Survey (NIS)—Since 2013, designation of place of residence as metropolitan or nonmetropolitan for NIS respondents is based on 2010 Census data and the MSAs delineated in February 2013. For data prior to 2013, designation of place of residence as metropolitan or nonmetropolitan for NIS respondents was based on 2000 Census data and the MSAs delineated in 2003, as well as the following versions and revisions of MSA definitions: for 2011 and 2012, on the December 2009 definitions; for 2010, on the November 2008 definitions, for New England, the county-based areas were used; for 2009, on the November 2007 definitions, for New England, the county-based areas were used; for 2008, on the December 2006 definitions, for New England, the county-based areas were used; for Quarter 4 of 2007, on the December 2006 definitions; for Quarters 1-3 of 2007, on the December 2005 definitions, for New England, the county-based areas were used in 2007; for 2006, on the November 2004 definitions, for New England, the county-based areas were used; for 2005, on the December 2003 definitions, for New England, the county-based areas were used; for Quarters 3 and 4 of 2004, on the December 2003 definitions; and for Quarters 1 and 2 of 2004 and Quarter 4 of 2003, on the June 2003 definitions. For 2003-2004 for New England, the county-based areas were used. For more information, see: https://www.census.gov/programs-surveys/metro-micro.html.

## Micropolitan statistical area

The Office of Management and Budget (OMB) defines a micropolitan statistical area as a nonmetropolitan county, or group of contiguous nonmetropolitan counties, that contains an urban cluster of 10,000-49,999 persons. A micropolitan statistical area may include surrounding counties that have strong social and economic ties with the central county or counties as measured by commuting. Nonmetropolitan counties that are not classified as part of a micropolitan statistical area are considered noncore.

OMB defines micropolitan statistical areas according to published standards that are applied to U.S. Census Bureau data. The standards are revised periodically, generally prior to the decennial census, and are applied to the census data to delineate the statistical areas Revisions to the areas are implemented between censuses using updated population estimates. The most recent standards were released in June 2010 (available from: https://www.whitehouse.gov/sites/whitehouse.gov/files/omb/federal_register/FR2010/06282010_metro_standards.pdf). OMB released a new delineation of the country’s metropolitan and micropolitan statistical areas based on the 2010 standards in July 2015 (available from: https://obamawhitehouse.archives.gov/sites/default/files/omb/bulletins/2015/15-01.pdf). Data for micropolitan statistical areas currently in Health, United States are based on the 2013-based delineation as part of the 2013 NCHS Urban-Rural Classification Scheme for Counties. The micropolitan statistical area data will be updated when the new delineation is incorporated into individual data systems.

For more information about micropolitan statistical areas, see: https://www.census.gov/programs-surveys/metro-micro.html. (Also see Appendix II, Metropolitan statistical area [MSA]; Urbanization.)

## Multum Lexicon Plus therapeutic class

Starting with 2003 data, the National Center for Health Statistics (NCHS) used Lexicon Plus (Cerner Multum, Inc., Denver, CO.), a proprietary database, to assist with data editing and classification of human drugs. Starting with 2005 data, Lexicon Plus has also been used to assist with data collection. Data collected before 2003 were updated by adding a generic drug code from Lexicon Plus.

Lexicon Plus is a comprehensive database of all prescription and some nonprescription drug products available in the U.S. drug market. It uses a three-level nested category system to assign a therapeutic classification to each drug (e.g., for atenolol: cardiovascular agents [level 1]; beta-adrenergic blocking agents [level 2]; cardioselective beta blockers [level 3]). Not all drugs have three classification levels; some may only have two (e.g., for diltiazem: cardiovascular agents [level 1]; calcium channel blocking agents [level 2]). Other drugs may have only one classification level. All drugs in NCHS surveys were assigned into a Lexicon Plus drug category, even those drugs not found in the Lexicon Plus drug database. “Unspecified” drugs were assigned to their respective therapeutic category (e.g., hormones/hormone modifiers-unspecified: category ID = 97, category name = hormones/hormone modifiers).

Data presented in the Health, United States trend table on prescription drug use by drug class are based on the second level of the Lexicon Plus nested category system (e.g., calcium channel blocking agents). A drug may have up to four drug therapeutic categories; drugs classified into more than one class were counted in each class. For example, if a person reported taking lorazepam, that respondent was classified as taking an anticonvulsant, an antiemetic/antivertigo agent, and an anxiolytic, sedative, hypnotic drug.

The drug information file is updated along with each cycle of prescription medication data release. Some new therapeutic categories could be added, and a few assigned classification levels might be changed (e.g., alendronate now has three classification levels: metabolic agents [level 1], bone resorption inhibitors [level 2], and bisphosphonates [level 3]); under the prior drug information file, alendronate had two classification levels: hormones [level 1] and bisphosphonates [level 2]. Data presented in Health, United States used the most recent drug information file for all data years. For more information, see: http://wwwn.cdc.gov/nchs/nhanes/1999-2000/RXQ_DRUG.htm.

## Neonatal mortality rate

See Appendix II, Rate: Death and related rates.

## Nonprofit hospital

See Appendix II, Hospital.

## North American Industry Classification System (NAICS)

See Appendix II, Industry of employment.

## Notifiable disease

A disease that, when diagnosed, requires health providers (usually by law) to report to state or local public health officials. Notifiable diseases are of public interest by reason of their contagiousness, severity, or frequency. For more information, see: https://wwwn.cdc.gov/nndss/

## Nursing home

In the Quality Improvement Evaluation System (formerly the Online Survey Certification and Reporting System), a nursing home is a facility that is certified and meets the Centers for Medicare & Medicaid Services’ long-term care requirements for Medicare and Medicaid eligibility.

After October 1, 1990, long-term care facilities that met the Omnibus Budget Reconciliation Act of 1987 (Pub. L. No. 100-203, 101 Stat. 1330) nursing home reform requirements and were formerly certified under Medicaid as skilled nursing, nursing home, or intermediate care facilities were reclassified as nursing facilities. Medicare continues to certify skilled nursing facilities but not intermediate care facilities. State Medicaid programs can certify intermediate care facilities for individuals with intellectual disabilities (formerly called mentally retarded) and the developmentally disabled. To be certified for participation in Medicaid, nursing facilities must also be certified to participate in Medicare (except those facilities that have obtained waivers). Thus, most nursing home care is now provided in skilled care facilities. (Also see Appendix II, Long-term care facility; Nursing home; Resident, health facility.)

## Nursing home expenditures

See Appendix II, Health expenditures, national.

## Obesity

See Appendix II, Body mass index (BMI).

## Occupancy rate

In American Hospital Association statistics, hospital occupancy rate is calculated as the average daily census divided by the number of hospital beds, cribs, and pediatric bassinets set up and staffed on the last day of the reporting period, expressed as a percentage. Average daily census is calculated by dividing the total annual number of inpatients, excluding newborns, by 365 days to derive the number of inpatients receiving care on an average day during the annual reporting period. The occupancy rate for facilities other than hospitals is calculated as the number of residents at the facility reported on the day of interview, divided by the number of reported beds. In the Centers for Medicare & Medicaid Services’ Quality Improvement Evaluation System (formerly the Online Survey Certification and Reporting System), occupancy is determined as of the day of certification inspection as the total number of residents on that day divided by the total number of beds on that day.

## Office-based physician

See Appendix II, Physician.

## Office visit

In the National Ambulatory Medical Care Survey, a physician’s ambulatory practice (office) can be in any location other than in a hospital, nursing home, other extended care facility, patient’s home, industrial clinic, college clinic, or family planning clinic. Offices in health maintenance organizations and private offices in hospitals are included. An office visit is any direct personal exchange between an ambulatory patient and a physician or members of his or her staff for the purpose of seeking care and rendering health services. (Also see Appendix II, Outpatient visit.)

## Operation

See Appendix II, Procedure.

## Outpatient department

According to the National Hospital Ambulatory Medical Care Survey (NHAMCS), an outpatient department (OPD) is a hospital facility where nonurgent ambulatory medical care is provided. The following types of OPDs are excluded from NHAMCS: ambulatory surgical centers, chemotherapy, employee health services, renal dialysis, methadone maintenance, and radiology. (Also see Appendix II, Emergency department; Outpatient visit.)

## Outpatient surgery

According to the American Hospital Association, outpatient surgery is a surgical operation, whether major or minor, performed on a patient who does not remain in the hospital overnight. Outpatient surgery may be performed in inpatient operating suites, outpatient surgery suites, or procedure rooms within an outpatient care facility. A surgical operation involving more than one surgical procedure is considered one surgical operation. (Also see Appendix II, Procedure.)

## Outpatient visit

The American Hospital Association defines outpatient visits as visits for receipt of medical, dental, or other services at a hospital by patients who are not lodged in the hospital Each appearance by an outpatient to each unit of the hospital is counted individually as an outpatient visit, including all clinic visits, referred visits, observation services, outpatient surgeries, and emergency department visits. In the National Hospital Ambulatory Medical Care Survey (NHAMCS), an outpatient department visit is a direct personal exchange between a patient and a physician or other health care provider working under the physician’s supervision for the purpose of seeking care and receiving personal health services. (Also see Appendix II, Emergency department or emergency room visit; Outpatient department.)

## Overweight

See Appendix II, Body mass index (BMI).

## Pap smear

A Pap smear (also known as a Papanicolaou smear or Pap test) is a microscopic examination of cells scraped from the cervix that is used to detect cancerous or precancerous conditions of the cervix or other medical conditions.

In the National Health Interview Survey (NHIS), questions concerning Pap smear use are asked on an intermittent schedule, and the question content has differed slightly across years. For 2015, women were asked when they had their most recent Pap smear, and use of Pap smears was defined as “percent of women having a Pap smear within the past 3 years.” Survey questions have changed over time.

In 1987, women were asked to report either the month and year of their Pap smear or the amount of time (in days, weeks, months, or years) elapsed since their last Pap smear. Women who did not respond were asked, “Was it within the past year or a year or more ago?” Those who answered “within the past year” were asked to further clarify whether the Pap smear was less than 3 months or 3 or more months ago, and those who answered “a year or more ago” were asked to further clarify whether the Pap smear was 3 years or less, between 3 and 5 years, or 5 or more years ago.

In 1990 and 1991, Pap smear data in the past 3 years were not available. In 1993 and 1994, women were asked whether they had a Pap smear within the past year, between 1 and 3 years ago, or more than 3 years ago. In 1998, women were asked whether they had a Pap smear 1 year ago or less, more than 1 year but not more than 2 years ago, more than 2 years but not more than 3 years ago, more than 3 years but not more than 5 years ago, or more than 5 years ago.

In 1999, women were asked when they had their most recent Pap smear (time elapsed in days, weeks, months, or years). Women who did not respond were asked whether they had a Pap smear a year ago or less, more than 1 year but not more than 2 years ago, more than 2 years but not more than 3 years ago, more than 3 years but not more than 5 years ago, or more than 5 years ago. Estimates for 1999 may be slightly overestimated in comparison with estimates for previous years due to the inclusion of women who responded “3 years ago” (4% of women), which could have included more than 3 years but less than 4 years.

In 2000 and 2003, women were asked when they had their most recent Pap smear (month and year). Women who did not respond were given a follow-up question that used the 1999 wording, and women who did not respond to the follow-up question were asked a second follow-up question that used the 1998 wording. Estimates for 2000 and 2003 may be slightly overestimated in comparison with years prior to 1999 due to the inclusion of women who responded “3 years ago” (less than 1% of women), which could have included more than 3 years but less than 4 years.

In 2005, women were asked the same series of questions about Pap smear use as in the 2000 and 2003 surveys, but the questionnaire skip pattern was modified so that more women were asked the follow-up question using the 1998 wording, and these women were not uniformly coded as having had a Pap smear within the past 3 years. Thus, estimates for 2005 are more precise than estimates for 1999, 2000, and 2003. SAS code to categorize Pap smear data for 2000 and beyond is available from: https://www.cdc.gov/nchs/nhis/nhis_2005_data_release.htm.

In 2008, 2010, 2013, and 2015, Pap smear questions were similar to those asked in 2005.

All women aged 18 and over were asked the Pap smear question(s). Women who reported having had a hysterectomy (removal of the uterus, with or without removal of the ovaries and cervix) were still asked the Pap smear questions because a woman who has had a hysterectomy may still have had Pap smear testing.

The current general recommendation, made by the U.S. Preventive Services Task Force (USPSTF) in 2012, is the use of Pap smears for cervical cancer every 3 years in women aged 21-65, with additional recommendations available for women aged 30-65 who want to lengthen the recommended screening interval. In Health, United States, 2014, additional age groups (18-20, 21-24, and 21-44) were added to account for the new recommendation. However, these recommendations were undergoing review by USPSTF at the time this report was prepared. For a summary of current Pap smear testing recommendations and the status of the review, see: https://www.uspreventiveservicestaskforce.org/Page/Document/UpdateSummaryFinal/cervical-cancer-screening and https://www.uspreventiveservicestaskforce.org/Page/Document/UpdateSummaryDraft/cervical-cancer-screening2.

USPSTF recommends against routine Pap smear screening in women who have had a total hysterectomy for benign disease. Therefore, two measures of Pap smear screening are presented in Health, United States: one among all women and one among women who did not report having a hysterectomy, although it is not known from NHIS data whether, for women who did report a hysterectomy, it was for benign disease. Questions about whether the respondent had a hysterectomy were not asked in 2003.

For other survey years, questions about hysterectomy in NHIS differed slightly, as follows.

In 1987, women who reported that they had not had a recent Pap smear were asked the most im portant reason they had not had a Pap smear; one reason women could select was “had a hysterectomy.” In 1993, 1994, 1998, 1999, 2013, and 2015, women were asked, “Have you had a hysterectomy?” In 2000, 2005, 2008, and 2010, two questions were used to determine whether women had a hysterectomy. Women were asked, “Have you had a hysterectomy?” In addition, women who reported that they had not had a recent Pap smear were asked the most important reason they had not had a Pap smear; one reason women could select was “had hysterectomy. “Women responding to either of these questions that they had a hysterectomy were excluded from the Health, United States estimates for the group “Percent of women having a Pap smear within the past 3 years, among those who have not had a hysterectomy.”

## Patient

See Appendix II, Inpatient; Office visit; Outpatient visit.

## Percent change/percentage change

See Appendix II, Average annual rate of change (percent change).

## Perinatal mortality rate; ratio

See Appendix II, Rate: Death and related rates.

## Personal care home with or without nursing

See Appendix II, Nursing home.

## Personal health care expenditures

See Appendix II, Health expenditures, national.

## Physical activity, leisure-time

Starting with Health, United States, 2010, estimates on leisure-time physical activity changed to reflect the federal 2008 Physical Activity Guidelines for Americans (available from: https://health.gov/PAGuidelines/guidelines/default.aspx). Adults who met the 2008 guidelines reported at least 150 minutes per week of moderate-intensity aerobic physical activity or 75 minutes per week of vigorous-intensity aerobic physical activity (or an equivalent combination of moderate- and vigorous-intensity aerobic activity) and muscle-strengthening activities at least twice a week. The estimates for the percentage of Americans who met the 2008 guidelines for aerobic physical activity and muscle strengthening are not comparable with estimates in previous editions of Health, United States that showed the percentage of Americans with regular leisure-time physical activity. For more information, see: Carlson SA, Fulton JE, Schoenborn CA, Loustalot F. Trend and prevalence estimates based on the 2008 Physical Activity Guidelines for Americans. Am J Prev Med 39(4)305-13.2010.

Starting with 1998 data, leisure-time physical activity has been assessed in the National Health Interview Survey (NHIS) by asking adults a series of questions about how often they do vigorous or light or moderate physical activity of at least 10 minutes duration and about how long these sessions generally last. All questions related to leisure-time physical activity were phrased in terms of current behavior and lack a specific reference period. Vigorous physical activity is described as causing heavy sweating or a large increase in breathing or heart rate, and light or moderate as causing light sweating or a slight-to-moderate increase in breathing or heart rate. Adults were also asked about how often they did leisure-time physical activities specifically designed to strengthen their muscles, such as lifting weights or doing calisthenics. The 2008 guidelines recommend any kind of aerobic activity, not just leisure-time aerobic activity, so the leisure-time aerobic activity estimates presented in this report may underestimate the percentage of adults who met the 2008 guidelines for aerobic activity. For more information, see the NHIS Adult Physical Activity Information website at: https://www.cdc.gov/nchs/nhis/physical_activity.htm.

## Physician

Data on physician characteristics are obtained through physician self-report from the American Medical Association’s (AMA) Physician Masterfile. Although AMA collects data for both doctors of medicine and doctors of osteopathy (DOs), in Health, United States, data for DOs come from the American Osteopathic Association. (Also see Appendix II, Physician specialty.)

Active (or professionally active) physician—These physicians are currently engaged in patient care or other professional activity for a minimum of 20 hours per week. Other professional activity includes administration, medical teaching, research, and other activities such as employment with insurance carriers, pharmaceutical companies, corporations, voluntary organizations, and medical societies. Physicians who are retired, semiretired, working part-time, or not practicing are classified as inactive and are excluded. Also excluded are physicians with unknown addresses and physicians who did not provide information on type of practice or present employment (not classified).

Hospital-based physician—These physicians are employed under contract with hospitals to provide direct patient care and include physicians in residency training (including clinical fellows) and full-time members of the hospital staff.

Office-based physician—These physicians are engaged in seeing patients in solo practice, group practice, two-physician practice, other patient care employment, or in providing inpatient services such as those offered by pathologists and radiologists.

Data for physicians are presented by type of education (doctor of medicine or doctor of osteopathy); place of education (U.S. medical graduates and international medical graduates); activity status (professionally active and inactive); area of specialty; and geographic area.

## Physician specialty

Any specific branch of medicine in which a physician may concentrate. Data are based on physician self-reports of their primary area of specialty.

Physician data are broadly categorized into two areas of practice: those who provide primary care and those who provide specialty care. (Also see Appendix II, Physician.)

General primary care specialist—These physicians practice in the general fields of family medicine, general practice, internal medicine, obstetrics and gynecology, and pediatrics. Primary care specialists associated with these generalist fields are excluded.

Primary care subspecialist—These specialists practice in the primary care subspecialties of family medicine, internal medicine, obstetrics and gynecology, and pediatrics. Family medicine subspecialties include geriatric medicine and sports medicine. Internal medicine subspecialties include adolescent medicine, critical care medicine, diabetes, endocrinology, diabetes and metabolism, hematology, hepatology, hematology or oncology, cardiac electrophysiology, infectious diseases, clinical and laboratory immunology, geriatric medicine, sports medicine, nephrology, nutrition, medical oncology, pulmonary critical care medicine, and rheumatology Obstetrics and gynecology subspecialties include hospice and palliative medicine (obstetrics and gynecology), maternal and fetal medicine, critical care medicine (obstetrics and gynecology), and reproductive endocrinology. Pediatric subspecialties include adolescent medicine, pediatric critical care medicine, pediatrics or internal medicine, neonatal-perinatal medicine, pediatric allergy, pediatric cardiology, pediatric endocrinology, pediatric infectious disease, pediatric pulmonology, medical toxicology (pediatrics), pediatric emergency medicine, pediatric gastroenterology, pediatric hematology or oncology, clinical and laboratory immunology (pediatrics), pediatric nephrology, pediatric rheumatology, and sports medicine (pediatrics.)

Specialty care physician—These physicians are sometimes called specialists and include primary care specialists listed above in addition to all other physicians not included in the generalist definition. Specialty fields include allergy and immunology, aerospace medicine, anesthesiology, cardiovascular diseases, child and adolescent psychiatry, colon and rectal surgery, dermatology, diagnostic radiology, forensic pathology, gastroenterology, general surgery, medical genetics, neurology, nuclear medicine, neurological surgery, occupational medicine, ophthalmology, orthopedic surgery, otolaryngology, psychiatry, public health and general preventive medicine, physical medicine and rehabilitation, plastic surgery, anatomic and clinical pathology, pulmonary diseases, radiation oncology, thoracic surgery, urology, addiction medicine, critical care medicine, legal medicine, and clinical pharmacology.

Population—The U.S. Census Bureau collects and publishes data on populations in the United States according to several different definitions. Various statistical systems then use the appropriate population for calculating rates. (Also see Appendix I, Population Census and Population Estimates.)

Civilian noninstitutionalized population—Civilian population excluding persons residing in institutions (such as nursing homes, prisons, jails, mental hospitals, and juvenile correctional facilities). U.S. Census Bureau estimates of the civilian noninstitutionalized population are used to calculate sample weights for the National Health Interview Survey, the National Health and Nutrition Examination Survey, and the National Survey of Family Growth, and as denominators for rates calculated for the National Ambulatory Medical Care Survey and the National Hospital Ambulatory Medical Care Survey-Outpatient Department Component.

Civilian population—Resident population excluding members of the Armed Forces, although families of members of the Armed Forces are included. The civilian population is the denominator for emergency department visit rates using the National Hospital Ambulatory Medical Care Survey-Emergency Department Component.

Resident population—Includes persons whose usual place of residence (i.e., the place where one usually lives and sleeps) is in 1 of the 50 states or the District of Columbia. It includes members of the Armed Forces stationed in the United States and their families. It excludes members of the Armed Forces stationed outside the United States and civilian U.S. citizens whose usual place of residence is outside the United States The resident population is the denominator used to calculate birth and death rates and incidence of disease.

## Postneonatal mortality rate

See Appendix II, Rate: Death and related rates.

## Poverty

Two related versions of federal poverty measures are shown in Health, United States. The first measure—a ratio of family income to federal poverty threshold—is constructed using poverty thresholds from the U.S. Census Bureau. Poverty thresholds are updated annually for inflation by the U.S. Census Bureau using the Consumer Price Index for all urban consumers (CPI-U). Poverty thresholds include a set of money income thresholds that vary by family size and composition but do not vary geographically. Families or individuals with income below the appropriate threshold are classified as below poverty. For example, the weighted average poverty threshold for a family of four was $24,563 in 2016, $24,257 in 2015, $24,230 in 2014, $22,314 in 2010, $17,603 in 2000, and $13,359 in 1990. For more information, see the U.S. Census Bureau’s poverty threshold website at: https://www.census.gov/data/tables/time-series/demo/income-poverty/historical-poverty-thresholds.html.

The second poverty measure used in Health, United States is a ratio of family income to the U.S. Department of Health and Human Services (HHS) poverty guidelines. Poverty guidelines are derived from the U.S. Census Bureau’s poverty thresholds and are issued annually by HHS. These guidelines are often used to determine eligibility in certain federal programs. The HHS poverty guidelines take into account family size and state (coterminous states, Alaska, Hawaii), but not family composition. For more information, see the HHS “Poverty Guidelines, Research, and Measurement” website at: https://aspe.hhs.gov/poverty-research.

National Health and Nutrition Examination Survey (NHANES)— NHANES uses the U.S. Census Bureau’s Current Population Survey definition of family to group household members into a family unit. A poverty ratio is computed by dividing family income by the HHS poverty guidelines specific to family size, as well as the appropriate guideline year, and state. See: Johnson CL, Paulose-Ram R, Ogden CL, Carroll MD, Kruszon-Moran D, Dohrmann SM, Curtin LR. National Health and Nutrition Examination Survey: Analytic guidelines, 1999-2010. National Center for Health Statistics. Vital Health Stat 2(161). 2013. Available from: https://www.cdc.gov/nchs/data/series/sr_02/sr02_161.pdf.

National Health Interview Survey—For data years prior to 1997, a ratio of family income to U.S. Census Bureau poverty threshold was computed taking into account family income and family size. Starting with 1997 data, the poverty ratio was based on family income, family size, and family composition (number of children in the family, and for families with two or fewer adults, the age of the adults in the family). (Also see Appendix II, Consumer Price Index [CPI]; Family income; and Appendix I, Current Population Survey [CPS]; National Health Interview Survey [NHIS].)

## Preferred provider organization

A type of medical plan in which coverage is provided to participants through a network of selected health care providers, such as hospitals and physicians. Enrollees may seek care outside the network but pay a greater percentage of the cost of coverage than within the network. (Also see Appendix II, Health maintenance organization [HMO]; Managed care.)

## Prevalence

The number of cases of a disease, number of infected persons, or number of persons with some other attribute present during a particular interval of time. It is often expressed as a rate (e.g., the prevalence of diabetes per 1,000 persons during a year). (Also see Appendix II, Incidence.)

## Primary care specialty

See Appendix II, Physician specialty.

## Private expenditures

See Appendix II, Health expenditures, national.

## Procedure

Can include surgical procedures (such as appendectomies), diagnostic procedures (such as spinal taps), and therapeutic treatments (such as infusion of a cancer chemotherapeutic substance) reported on a patient’s medical record. In Health, United States, procedures are coded according to the International Classification of Diseases, 9th Revision, Clinical Modification (ICD-9-CM) until 2016 data are available, and then procedures will be classified using the International Classification of Diseases, 10th Revision, Clinical Modification/Procedure Coding System (ICD-10-CM/PCS).

Healthcare Cost and Utilization Project, National (Nationwide) Inpatient Sample (HCUP-NIS)—Currently, up to 15 procedures are coded using ICD-9-CM procedure codes per hospital stay in the HCUP-NIS database. On October 1, 2015, the United States transitioned to the International Classification of Diseases, 10th Revision, Clinical Modification (ICD-10-CM) diagnosis coding system for most inpatient and outpatient medical encounters and the International Classification of Diseases, 10th Revision, Procedure Coding System (ICD-10-PCS) for inpatient hospital procedures. Because of the impact of this transition to ICD-10-CM/PCS, and because full calendar year data for 2015 are not available using one ICD system, the Health, United States table has not been updated with 2015 data. Starting with 2016 data, procedures will be coded according to ICD-10-CM/PCS. For each record, a principal procedure is identified as the first procedure listed HCUP-NIS procedure data presented in Health, United States are limited to operating room procedures that are principal procedures (first-listed). Valid operating room procedures were identified according to diagnosis-related groups (DRGs) software. For DRG development, physician panels classify all ICD-9-CM procedure codes based on whether the procedure would be performed in operating rooms in most hospitals. Clinical Classifications Software (CCS) was used to categorize ICD-9-CM principal operating room procedure codes into 1 of 231 clinically meaningful categories. CCS was developed at the Agency for Healthcare Research and Quality as a tool for clustering patient procedures into a manageable number of clinically meaningful categories. It is periodically updated. For more information on CCS, see: https://www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp. The top-ranking operating room procedure categories by age group, based on the number of discharges and total national costs, are presented in Health, United States (Table XI). CCS categories labeled “other” are not presented because these comprise miscellaneous procedures that do not form a homogeneous group. (Also see Appendix II, Outpatient surgery.)

## Proprietary hospital

See Appendix II, Hospital.

## Public expenditures

See Appendix II, Health expenditures, national.

## Purchasing power parities (PPPs)

Calculated rates of currency conversion that equalize the purchasing power of different currencies by eliminating the differences in price levels between countries. PPPs show the ratio of prices in national currencies for the same good or service in different countries PPPs can be used to make intercountry comparisons of the gross domestic product and its component expenditures. (Also see Appendix II, Gross domestic product [GDP].)

## Race

In 1977, the Office of Management and Budget (OMB) issued Race and Ethnic Standards for Federal Statistics and Administrative Reporting (Statistical Policy Directive 15) to promote comparability of data among federal data systems. The 1977 Standards called for the federal government’s data systems to classify individuals into the following four racial groups: American Indian or Alaskan Native, Asian or Pacific Islander, black, and white. Depending on the data source, the classification by race was based on self-classification or on observation by an interviewer or other person filling out the questionnaire.

In 1997, revisions were announced for classification of individuals by race within the federal government’s data systems (see: Revisions to the standards for the classification of federal data on race and ethnicity. Fed Regist 62(210):58782-90. 1997). The 1997 Standards specify five racial groups: American Indian or Alaska Native, Asian, black or African American, Native Hawaiian or Other Pacific Islander, and white. These five categories are the minimum set for data on race in federal statistics. The 1997 Standards also offer an opportunity for respondents to select more than one of the five groups, leading to many possible multiple-race categories. As with the single-race groups, data for the multiple-race groups are to be reported when estimates meet agency requirements for reliability and confidentiality. The 1997 Standards allow for observer or proxy identification of race but clearly state a preference for self-classification. The federal government considers race and Hispanic origin to be two separate and distinct concepts. Thus, Hispanic persons may be of any race. Federal data systems were required to comply with the 1997 Standards by 2003.

Birth file—Information about the race and Hispanic origin of the mother and father is provided by the mother at the time of birth and is recorded on the birth certificate or fetal death record. Since 1980, birth rates, birth characteristics, and death rates for live-born infants and fetal deaths are presented in Health, United States according to race of the mother. Before 1980, data were tabulated by race of the newborn and fetus, taking into account the race of both parents. If the parents were of different races and one parent was white, the child was classified according to the race of the other parent. When neither parent was white, the child was classified according to father’s race, with one exception: if either parent was Hawaiian, the child was classified as Hawaiian. Before 1964, if race was unknown, the birth was classified as white. Starting in 1964, unknown race was classified according to information on the birth record. Starting with the 2000 Census, the race and ethnicity data used for denominators (population) to calculate birth and fertility rates have been collected in accordance with the 1997 revised OMB standards for race and ethnicity. However, the numerators (births) will not be compatible with the denominators until all the states revise their birth certificates to reflect the new standards. To compute rates, it is currently necessary to bridge population data for multiple-race persons to single-race categories. (Also see Appendix I, Population Census and Population Estimates, Bridged-race Population Estimates.)

Starting with 2003 data, some states began using the 2003 revision of the U.S. Standard Certificate of Live Birth, which allows the reporting of more than one race (multiple races). As of January 1, 2016, all states and the District of Columbia (D.C.), in addition to Puerto Rico, the U.S. Virgin Islands, Guam, and Northern Marianas, used the 2003 revision of the U.S. Standard Certificate of Live Birth and reported race according to the 1997 revised OMB standards. In 2016, 2. 5% of mothers in the 50 U.S. states and D.C. reported more than one race. To provide uniformity and comparability of data for trend comparison, bridged single-race categories are still presented in Health, United States. For more information on the adoption of the 2003 revision of the U.S. Standard Certificate of Live Birth, see the Technical Notes section of the annual series of “Births: Final Data” reports, available from: https://www.cdc.gov/nchs/products/nvsr.htm.

Although the bridging procedure imputes multiple race of mothers to one of the four minimum races stipulated in the 1977 Standards, mothers of a specified Asian or Pacific Islander (API) subgroup (Chinese, Japanese, Hawaiian, or Filipino) in combination with another race (American Indian or Alaska Native, black, or white) or another API subgroup cannot be imputed to a single API subgroup. Data for the API subgroups from all states and D.C. are available starting with the 2016 Natality public-use data file at: https://www.cdc.gov/nchs/births.htm.

Mortality file—Information about the race and Hispanic origin of a decedent is reported by the funeral director as provided by an informant (often the surviving next of kin), or in the absence of an informant, on the basis of observation. Death rates by race and Hispanic origin are based on information from death certificates (numerators of the rates) and on population estimates from the U.S. Census Bureau (denominators). Race and ethnicity information from the census is by self-report. To the extent that race and Hispanic origin are inconsistent between these two data sources, death rates will be biased. Studies have shown that persons self-reported as American Indian, Asian, or Hispanic on census and survey records may sometimes be reported as white or non-Hispanic on the death certificate, resulting in an underestimation of deaths and death rates for the American Indian, Asian, and Hispanic groups. Bias also results from undercounts of some population groups in the census—particularly young black males, young white males, and elderly persons—resulting in an overestimation of death rates.

Race and ethnicity reporting on the death certificate continues to be excellent for the white and black populations. It remains poor for the American Indian or Alaska Native population but is reasonably good for the Hispanic and Asian or Pacific Islander populations. Decedent characteristics such as place of residence and nativity have an important effect on the quality of reporting on the death certificate. The effects of misclassification on mortality estimates were most pronounced for the American Indian or Alaska Native population, where correcting for misclassification reverses a large American Indian or Alaska Native-over-white mortality advantage to a relatively large disadvantage. Among the Hispanic and Asian or Pacific Islander populations, adjustment for death certificate misclassification did not significantly affect minority-majority mortality. For more information, see: Arias E, Heron M, Hakes JK. The validity of race and Hispanic-origin reporting on death certificates in the United States: An update. National Center for Health Statistics. Vital Health Stat 2(172). 2016. Available from: https://www.cdc.gov/nchs/data/series/sr_02/sr02_172.pdf; and Arias E, Schauman WS, Eschbach K, Sorlie PD, Backlund E. The validity of race and Hispanic origin reporting on death certificates in the United States. National Center for Health Statistics. Vital Health Stat 2(148). 2008. Available from: https://www.cdc.gov/nchs/data/series/sr_02/sr02_148.pdf.

Denominators for infant mortality rates are based on the number of live births, rather than on population estimates. Race information for the denominator is supplied from the birth certificate. Before 1980, race of child for the denominator took into account the races of both parents. Starting in 1980, race information for the denominator has been based solely on the race of the mother. Race information for the numerator is supplied from the death certificate. For the infant mortality rate, race information for the numerator is race of the deceased child.

Issues affecting the interpretation of vital event rates for the American Indian or Alaska Native population include (a) changes in the classification or self-identification of persons of American Indian or Alaska Native heritage over time, and (b) misclassification of American Indian or Alaska Native persons on death certificates by the funeral director or informant. Vital event rates for the American Indian or Alaska Native population shown in Health, United States are based on the total U.S. resident American Indian or Alaska Native population, as enumerated by the U.S. Census Bureau.

In contrast, the Indian Health Service calculates vital event rates for this population based on U.S. Census Bureau county data for American Indian or Alaska Native persons who reside on or near reservations. Because of misclassification of American Indian or Alaska Native persons on death certificates, American Indian or Alaska Native national and state-specific mortality estimates published in Health, United States should be interpreted with caution.

Interpretation of trends for the Asian population in the United States should take into account that this population more than doubled between 1980 and 1990, primarily because of immigration. Between 1990 and 2000, the increase in the Asian population was 48% for persons reporting that they were Asian alone and 72% for persons who reported they were either Asian alone or Asian in combination with another race.

For more information on coding race by using vital statistics, see: National Center for Health Statistics. Vital statistics of the United States, vol I, Natality, and vol II, Mortality, part A, Technical appendix. Published annually, available from: https://www.cdc.gov/nchs/products/vsus/ta.htm.

Starting with 2003 data, some states began using the 2003 revision of the U.S. Standard Certificate of Death, which allows the reporting of more than one race (multiple races). This change was implemented to reflect the increasing diversity of the U.S. population and to be consistent with the decennial census. For more information on states’ reporting of multiple-race data, see the annual series of “Deaths: Final Data” reports, available from: https://www.cdc.gov/nchs/products/nvsr.htm.

To provide uniformity and comparability of data until all states are reporting multiple-race data, it has been necessary to bridge the responses of those for whom more than one race is reported (multiple race) to one single race. For more information, see: National Center for Health Statistics. NCHS procedures for multiple-race and Hispanic origin data: Collection, coding, editing, and transmitting. 2004. Available from: https://www.cdc.gov/nchs/data/dvs/Multiple_race_docu_5-10-04.pdf; and National Center for Health Statistics. Vital statistics of the United States, vol I, Natality, and vol II, Mortality, part A, Technical appendix. Published annually, available from: https://www.cdc.gov/nchs/nvss.htm.

National Health and Nutrition Examination Survey (NHANES)—Starting with Health, United States, 2003, race-specific estimates based on NHANES were tabulated using the 1997 Standards for data years 1999 and beyond. Prior to data year 1999, the 1977 Standards were used. Because of the differences between the two standards, the race-specific estimates shown in trend tables presenting NHANES data for 1999 and beyond are not strictly comparable with estimates for earlier data years. Race in NHANES I and II was determined primarily by interviewer observation; starting with NHANES III, race was self-reported by survey participants.

The NHANES sample for data years 1999-2006 was designed to provide estimates specifically for persons of Mexican origin and not for all Hispanic-origin persons in the United States. Persons of Hispanic origin other than Mexican origin were entered into the sample with different selection probabilities that are not nationally representative of the total U.S. Hispanic population. Starting with 2007-2008 data, all Hispanic persons were oversampled, not just persons of Mexican origin. Oversampling of the black population was continued. Starting in 2011, NHANES oversampled the non-Hispanic Asian population. In Health, United States, estimates are shown for non-Hispanic white, non-Hispanic black, and Mexican-origin persons, as well as for Hispanic-origin and non-Hispanic Asian persons, where possible Although data were collected according to the 1997 Standards, there are insufficient numbers of observations during this period to meet statistical reliability or confidentiality requirements for reporting estimates for additional race categories.

National Health Care Surveys—Estimates by racial group based on the National Ambulatory Medical Care Survey (NAMCS) and the National Hospital Ambulatory Medical Care Survey (NHAMCS) should be used with caution because information on race was collected from medical records and race is imputed for records missing that information. In 2015, race data were missing and imputed for 26% of NAMCS visits and 19% of NHAMCS-Emergency Department visits. For more information on the race imputation process used in each data year, see the public-use file documentation, available from: https://www.cdc.gov/nchs/ahcd/index.htm. Starting with 1999 data, the instruction for the race item on the Patient Record Form was changed so that more than one race could be recorded. In previous years only one race could be recorded. Estimates by racial group presented in Health, United States are for visits where only one race was recorded. Because of the small number of responses with more than one racial group recorded, estimates for visits with multiple races recorded are unreliable and are not presented.

National Health Interview Survey (NHIS)—Starting with Health, United States, 2002, race-specific estimates based on NHIS were tabulated using the 1997 Standards for data year 1999 and beyond and are not strictly comparable with estimates for earlier years. The 1997 Standards specify five single-race categories and multiple-race categories. Estimates for specific race groups are shown when they meet requirements for statistical reliability and confidentiality. The race categories white only, black or African American only, American Indian or Alaska Native only, Asian only, and Native Hawaiian or Other Pacific Islander only include persons who reported only one racial group; the category 2 or more races includes persons who reported more than one of the five racial groups in the 1997 Standards or one of the five racial groups and “some other race.” In order to maintain consistency with the U.S. Census Bureau procedures for collecting and editing data on race and ethnicity, NHIS made major changes to its editing procedures in the 2003 data year. Beginning with the 2003 NHIS, Other Race was no longer available as a separate race response. This response category was treated as missing, and the race was imputed if this was the only race response. In cases where Other Race was mentioned along with one or more race groups, the Other Race response was dropped, and the race group information was retained.

Prior to data year 1999, data were tabulated according to the 1977 Standards, with four racial groups, and the Asian only category included Native Hawaiian or Other Pacific Islander. Estimates for single-race categories prior to 1999 included persons who reported one race, or if they reported more than one race, identified one race as best representing their race. Differences between estimates tabulated using the two standards for data year 1999 are discussed in the footnotes for each NHIS table in Health, United States 2002, 2003, and 2004 editions, available from: https://www.cdc.gov/nchs/hus/previous.htm#editions.

Tables XII and XIII illustrate NHIS data tabulated by race and Hispanic origin according to the 1997 and 1977 Standards for two health statistics (cigarette smoking and private health insurance coverage). In these examples, three separate tabulations using the 1997 Standards are shown: (a) race: mutually exclusive race groups, including several multiple-race combinations; (b) race, any mention: race groups that are not mutually exclusive because each race category includes all persons who mention that race; and (c) Hispanic origin and race: detailed race and Hispanic origin with a multiple-race total category. Where applicable, comparison tabulations by race and Hispanic origin are shown based on the 1977 Standards. Because there are more race groups with the 1997 Standards, the sample size of each race group under the 1997 Standards is slightly smaller than the sample size under the 1977 Standards. Only those few multiple-race groups with sufficient numbers of observations to meet standards of statistical reliability are shown. These tables also illustrate changes in labels and group categories resulting from the 1997 Standards. The race designation “black” was changed to “black or African American,” and the ethnicity designation “Hispanic” was changed to “Hispanic or Latino.”

Survey data included in Health, United States, other than NHIS, the National Survey of Drug Use and Health (NSDUH), and the National Health and Nutrition Examination Survey (NHANES), generally do not permit tabulation of estimates for the detailed race and ethnicity categories shown in Tables XII and XIII, either because race data based on the 1997 Standards categories are not yet available or because there are insufficient numbers of observations in certain subpopulation groups to meet statistical reliability or confidentiality requirements.

To improve the quality of data on ethnicity and race in NHIS, hot-deck imputation of selected race and ethnicity variables was done for the first time in the 2000 NHIS and continued to be used for subsequent data years. Starting with 2003 data, records for persons for whom “other race” was the only race response were treated as having missing data on race and were added to the pool of records for which selected race and ethnicity variables were imputed. Prior to the 2000 NHIS, a crude imputation method that assigned a race to persons with missing values for the variable MAINRACE (the respondent’s classification of the race he or she most identified with) was used. Under these procedures, if an observed race was recorded by the interviewer, it was used to code a race value. If there was no observed race value, all persons who had a missing value for MAINRACE and were identified as Hispanic on the Hispanic-origin question were coded as white. In all other cases, non-Hispanic persons were coded as “other race.” Additional information on the NHIS methodology for imputing race and ethnicity is available from the survey documentation at: https://www.cdc.gov/nchs/nhis/quest_data_related_1997_forward.htm, and from the NHIS race and Hispanic-origin home page at: https://www.cdc.gov/nchs/nhis/rhoi.htm.

National Survey on Drug Use and Health (NSDUH)—Race-specific estimates based on NSDUH are tabulated using the 1997 Standards. Estimates in the NSDUH trend table begin with data year 2002 Estimates for specific race groups are shown when they meet requirements for statistical reliability and confidentiality. The race categories white only, black or African American only, American Indian or Alaska Native only, Asian only, and Native Hawaiian or Other Pacific Islander only include persons who reported only one racial group; the category 2 or more races includes persons who reported more than one of the five racial groups in the 1997 Standards or one of the five racial groups and “some other race.”

National Vital Statistics System (NVSS)—In 2003, revised birth and death certificates were introduced with revised race and ethnicity sections conforming to the 1997 Standards on race and ethnicity. The new certificates were adopted on a rolling basis by states, territories, and other reporting areas. During the transition to full implementation of the 1997 Standards, in Health, United States vital statistics data will continue to be presented for four major race groups (white, black or African American, American Indian or Alaska Native, and Asian or Pacific Islander) in accordance with the 1977 Standards. In 2016, all states, territories, and reporting areas (except American Samoa) had adopted the 2003 revision of U.S. Standard Certificate of Live Birth. Some reporting areas in the Vital Statistics Cooperative Program are still revising their death records to conform to the 1997 Standards on race and ethnicity.

Youth Risk Behavior Surveillance System (YRBSS)—Prior to 1999, the 1977 OMB Standards were used. Respondents could select only one of the following categories: white (not Hispanic), black (not Hispanic), Hispanic or Latino, Asian or Pacific Islander, American Indian or Alaska Native, or other. Beginning in 1999, the 1997 OMB Standards were used for race-specific estimates, and respondents were given the option of selecting more than one category to describe their race and ethnicity. Between 1999 and 2003, respondents were asked a single question about race and Hispanic origin, with the option of choosing more than one of the following responses: white, black or African American, Hispanic or Latino, Asian, Native Hawaiian or Other Pacific Islander, or American Indian or Alaska Native. In 2005, respondents were asked a question about Hispanic origin (“Are you Hispanic or Latino?”) and a second separate question about race that included the option of selecting more than one of the following categories: American Indian or Alaska Native, Asian, black or African American, Native Hawaiian or Other Pacific Islander, or white. Because of the differences between questions, data about race and Hispanic ethnicity for the years prior to 1999 are not strictly comparable with estimates for the later years. However, analyses of data collected between 1991 and 2003 have indicated that the data are comparable across years and can be used to study trends. See: Brener ND, Kann L, McManus T. A comparison of two survey questions on race and ethnicity among high school students. Public Opin Q67(2):227-36 2003 (Also see Appendix II, Hispanic origin; and Appendix I, Population Census and Population Estimates.)

Table XII Current cigarette smoking among adults aged 18 and over, by race and Hispanic origin under the 1997 and 1977 Standards for federal data on race and ethnicity: United States, average annual 1993-1995

1997 Standards | Sample size | Percent (standard error) | 1977 Standards | Sample size | Percent (standard error)
White only | 46,228 | 25.2 (0.26) | White | 46,664 | 25.3 (0.26)
Black or African American only | 7,208 | 26.6 (0.64) | Black | 7,334 | 26.5 (0.63)
American Indian or Alaska Native only | 416 | 32.9 (2.53) | American Indian or Alaskan Native | 480 | 33.9 (2.38)
Asian only | 1,370 | 15.0 (1.19) | Asian or Pacific Islander | 1,411 | 15.5 (1.22)
2 or more races total | 786 | 34.5 (2.00)
Black or African American; white | 83 | *21.7 (6.05)
American Indian or Alaska Native; white | 461 | 40.0 (2.58)
Race, any mention
White, any mention | 46,882 | 25.3 (0.26)
Black or African American, any mention | 7,382 | 26.6 (0.63)
American Indian or Alaska Native, any mention | 965 | 36.3 (1.71)
Asian, any mention | 1,458 | 15.7 (1.20)
Native Hawaiian or Other Pacific Islander, any mention | 53 | *17.5 (5.10)
Hispanic origin and race
Not Hispanic or Latino: | | | Non-Hispanic:
White only | 42,421 | 25.8 (0.27) | White | 42,976 | 25.9 (0.27)
Black or African American only | 7,053 | 26.7 (0.65) | Black | 7,203 | 26.7 (0.64)
American Indian or Alaska Native only | 358 | 33.5 (2.69) | American Indian or Alaskan Native | 407 | 35.4 (2.53)
Asian only | 1,320 | 14.8 (1.21) | Asian or Pacific Islander | 1,397 | 15.3 (1.24)
2 or more races total | 687 | 35.6 (2.15)
Hispanic or Latino | 5,175 | 17.8 (0.65) | Hispanic | 5,175 | 17.8 (0.65)

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error of 20%-30%.

NOTES: The Office of Management and Budget’s (OMB) 1997 Revisions to the Standards for the Classification of Federal Data on Race and Ethnicity specify five race groups (white, black or African American, American Indian or Alaska Native, Asian, and Native Hawaiian or Other Pacific Islander) and allow respondents to report one or more race groups. Estimates for single-race and multiple-race groups not shown above do not meet standards for statistical reliability or confidentiality (relative standard error greater than 30%). Race groups under the 1997 Standards were based on the question, “What is the group or groups which represent [person’s] race?" For persons who selected multiple groups, race groups under the OMB’s 1977 Race and Ethnic Standards for Federal Statistics and Administrative Reporting were based on the additional question, “Which of those groups would you say best represents [person’s] race?" Race-specific estimates in this table were calculated after excluding respondents of other and unknown race. Other published race-specific estimates are based on files in which such responses have been edited. Estimates are age-adjusted to the year 2000 standard population using five age groups: 18-24, 25-34, 35-44, 45-64, and 65 and over. See Appendix II, Age adjustment.

SOURCE: NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Table XIII Private health care coverage among persons under age 65, by race and Hispanic origin under the 1997 and 1977 Standards for federal data on race and ethnicity: United States, average annual 1993-1995

1997 Standards | Sample size | Percent (standard error) | 1977 Standards | Sample size | Percent (standard error)
White only | 168,256 | 76.1 (0.28) | White | 170,472 | 75.9 (0.28)
Black or African American only | 30,048 | 53.5 (0.63) | Black | 30,690 | 53.6 (0.63)
American Indian or Alaska Native only | 2,003 | 44.2 (1.97) | American Indian or Alaskan Native | 2,316 | 43.5 (1.85)
Asian only | 6,896 | 68.0 (1.39) | Asian or Pacific Islander | 7,146 | 68.2 (1.34)
Native Hawaiian or Other Pacific Islander only | 173 | 75.0 (7.43)
2 or more races total | 4,203 | 60.9 (1.17)
Black or African American; white | 686 | 59.5 (3.21)
American Indian or Alaska Native; white | 2,022 | 60.0 (1.71)
Asian; white | 590 | 71.9 (3.39)
Native Hawaiian or Other Pacific Islander; white | 56 | 59.2 (10.65)
Race, any mention
White, any mention | 171,817 | 75.8 (0.28)
Black or African American, any mention | 31,147 | 53.6 (0.62)
American Indian or Alaska Native, any mention | 4,365 | 52.4 (1.40)
Asian, any mention | 7,639 | 68.4 (1.27)
Native Hawaiian or Other Pacific Islander, any mention | 283 | 68.7 (6.23)
Hispanic origin and race
Not Hispanic or Latino: | | | Non-Hispanic:
White only | 146,109 | 78.9 (0.27) | White | 149,057 | 78.6 (0.27)
Black or African American only | 29,250 | 53.9 (0.64) | Black | 29,877 | 54.0 (0.63)
American Indian or Alaska Native only | 1,620 | 45.2 (2.15) | American Indian or Alaskan Native | 1,859 | 44.6 (2.05)
Asian only | 6,623 | 68.2 (1.43) | Asian or Pacific Islander | 6,999 | 68.4 (1.40)
Native Hawaiian or Other Pacific Islander only | 145 | 76.4 (7.79)
2 or more races total | 3,365 | 62.6 (1.18)
Hispanic or Latino | 31,040 | 48.8 (0.74) | Hispanic | 31,040 | 48.8 (0.74)

NOTES: The Office of Management and Budget’s (OMB) 1997 Revisions to the Standards for the Classification of Federal Data on Race and Ethnicity specify five race groups (white, black or African American, American Indian or Alaska Native, Asian, and Native Hawaiian or Other Pacific Islander) and allow respondents to report one or more race groups. Estimates for single-race and multiple-race groups not shown above do not meet standards for statistical reliability or confidentiality (relative standard error greater than 30%). Race groups under the 1997 Standards were based on the question, “What is the group or groups which represent [person’s] race?" For persons who selected multiple groups, race groups under the OMB’s 1977 Race and Ethnic Standards for Federal Statistics and Administrative Reporting were based on the additional question, “Which of those groups would you say best represents [person’s] race?" Race-specific estimates in this table were calculated after excluding respondents of other and unknown race. Other published race-specific estimates are based on files in which such responses have been edited. Estimates are age-adjusted to the year 2000 standard population using three age groups: under 18, 18-44, and 45-64. See Appendix II, Age adjustment.

SOURCE: NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

## Rate

A measure of some event, disease, or condition in relation to a unit of population, along with some specification of time. (Also see Appendix II, Age adjustment; Population.)

Birth and related rates

Birth rate—Calculated by dividing the number of live births in a population in a year by the resident population. For census years, rates are based on unrounded census counts of the resident population as of April 1. For the noncensus years 1981-1989, rates are based on national estimates of the resident population as of July 1, rounded to thousands. Rounded population estimates for 5-year age groups are calculated by summing unrounded population estimates before rounding to thousands. Starting in 1991, rates are based on unrounded national population estimates Birth rates for 1991-1999 were revised based on the 1990 and 2000 Censuses. The rates for 1990, 2000, and 2010 are based on populations from the censuses in those years as of April 1 Birth rates for 2001-2009 were revised based on the 2000 and 2010 Censuses. Birth rates for 2011 and subsequent years were computed using 2010-based postcensal estimates. The population estimates have been provided by the U.S. Census Bureau and have been modified to be consistent with OMB racial categories as of 1977 and historical categories for birth data. Beginning in 1997, the birth rate for the maternal age group 45-49 includes data for mothers aged 50-54 in the numerator and is based on the population of women aged 45-49 in the denominator. Birth rates are expressed as the number of live births per 1,000 population. The rate may be restricted to births to women of specific age, race, marital status, or geographic location (specific rate), or it may be related to the entire population (crude rate.)

Fertility rate—Total number of live births, regardless of the age of the mother, per 1,000 women of reproductive age (aged 15-44). Beginning in 1997, the birth rate for the maternal age group 45-49 includes data for mothers aged 50-54 in the numerator and is based on the population of women aged 45-49 in the denominator.

Death and related rates

Death rate—Calculated by dividing the number of deaths in a population in a year by the midyear resident population. For census years, rates are based on unrounded census counts of the resident population as of April 1. For the noncensus years 1981-1989, rates are based on national estimates of the resident population as of July 1, rounded to thousands. Rounded population estimates for 10-year age groups are calculated by summing unrounded population estimates before rounding to thousands. Starting in 1991, rates are based on unrounded national population estimates Rates for the Hispanic and non-Hispanic white populations in each year are based on unrounded state population estimates for states in the Hispanic reporting area. Death rates are expressed as the number of deaths per 100,000 resident population. The rate may be restricted to deaths in specific age, race, sex, or geographic groups or from specific causes of death (specific rate), or it may be related to the entire population (crude rate). (Also see Appendix I, Population Census and Population Estimates.)

Birth cohort infant mortality rates—Based on the birth cohort linked birth and infant death files and computed as the number of deaths under age 1 year to members of the birth cohort, divided by the number of live births, times 1,000. (Also see Appendix II, Birth cohort.)

Fetal mortality rate—Number of fetal deaths with stated or presumed gestation of 20 weeks or more, divided by the sum of live births plus fetal deaths, times 1,000.

Infant mortality rate—Based on period files and calculated by dividing the number of infant deaths during a calendar year by the number of live births reported in the same year. It is expressed as the number of infant deaths per 1,000 live births. Neonatal mortality rate is the number of deaths among infants under age 28 days per 1,000 live births. Postneonatal mortality rate is the number of infant deaths that occur between 28 days to under 1 year after birth, per 1,000 live births. (Also see Appendix II, Infant death.)

Late fetal mortality rate—Number of fetal deaths with stated or presumed gestation of 28 weeks or more, divided by the sum of live births plus late fetal deaths, times 1,000. (Also see Appendix II, Gestation.)

Perinatal mortality rates and ratios—Relate to the period surrounding the birth event. Rates and ratios are based on events reported in a calendar year. Although several different perinatal mortality definitions exist, the perinatal definition used in Health, United States (and used most commonly for international comparisons) is the sum of late fetal deaths at 28 weeks of gestation or more plus infant deaths within 7 days of birth, divided by the sum of live births plus late fetal deaths, times 1,000. Perinatal mortality ratio is the sum of late fetal deaths plus infant deaths within 7 days of birth, divided by the number of live births, times 1,000.

Visit rate

Visit rate—A basic measure of service utilization for event-based data. Examples of events include physician office visits with drugs provided, or hospital discharges. In the visit rate calculation, the numerator is the number of estimated events, and the denominator is the corresponding U.S. population estimate for those who possibly could have had events during a given period of time. The interpretation is that for every person in the population there were, on average, x events. It does not mean that x persons in the population had events, because some persons in the population had no events while others had multiple events. The only exception is when an event can occur just once for a person (e.g., if an appendectomy is performed during a hospital stay). The visit rate is best used to compare utilization across various subgroups of interest, such as age or race groups or geographic regions.

## Region

See Appendix II, Geographic region.

## Registered hospital

See Appendix II, Hospital.

## Registration area

The United States has separate registration areas for birth, death, marriage, and divorce statistics. In general, registration areas correspond to states and include two separate registration areas for the District of Columbia (D.C.) and New York City. The term “reporting area” may be used interchangeably with the term “registration area.” All registration areas have adopted laws that require registration of births and deaths and the reporting of fetal deaths. It is believed that more than 99% of births and deaths occurring in this country are registered.

The death registration area was established in 1900 with 10 states and D.C., and the birth registration area was established in 1915, also with 10 states and D.C. Beginning in 1933, all states were included in the birth and death registration areas. The specific states added year by year are shown in: Hetzel AM. History and organization of the vital statistics system. National Center for Health Statistics. 1997. Available from: https://www.cdc.gov/nchs/data/misc/usvss.pdf. Currently, Puerto Rico, the U.S. Virgin Islands, and Guam each constitute a separate registration area, although their data are not included in statistical tabulations of U.S. resident data. (Also see Appendix II, Reporting area.)

## Relative standard error (RSE)

A measure of an estimate’s reliability. The RSE of an estimate is obtained by dividing the standard error of the estimate, SE(r), by the estimate itself, r. This quantity is expressed as a percentage of the estimate and is calculated as follows:

RSE = 100 × [ SE ( r ) / ( r ) ] RSE equals 100 times, open square bracket, S E, open bracket, R, close bracket, divided by, open bracket, R, close bracket, close square bracket.

Estimates with large RSEs are considered unreliable In Health, United States, most statistics with large RSEs are preceded by an asterisk or are not presented. The criteria for evaluating RSEs is discussed in the footnotes accompanying each table. In Health, United States, 2017, a multistep National Center for Health Statistics data presentation standard for proportions has replaced RSE to identify unreliable estimates of proportions from the 2015-2016 and 2013-2016 National Health and Nutrition Examination Surveys, the 2016 National Health Interview Survey, and the 2014-2015 National Ambulatory Medical Care Survey. (Also see Appendix II, Data presentation standard for proportions.)

## Relative survival rate

The ratio of the observed survival rate for the patient group to the expected survival rate for persons in the general population similar to the patient group with respect to age, sex, race, and calendar year of observation. The 5-year relative survival rate estimates the proportion of cancer patients who have survived their cancer 5 years after diagnosis. Because more than one-half of all cancers occur in persons aged 65 and over, many of these individuals die of other causes with no evidence of recurrence of their cancer. However, by adjusting observed survival for the normal life expectancy of the general population of the same age, the relative survival rate gives a more specific estimate of the chance of surviving the effects of cancer alone.

## Reporting area

In the National Vital Statistics System, the reporting area for basic items on the birth and death certificates such as age, race, and sex is based on data from residents of all 50 states in the United States, the District of Columbia, and New York City. The term “reporting area” may be used interchangeably with the term “registration area.” (Also see Appendix II, Registration area; and Appendix I, National Vital Statistics System [NVSS].)

## Resident, health facility

In the Centers for Medicare & Medicaid Services’ Quality Improvement Evaluation System (formerly the Online Survey Certification and Reporting System), all residents in certified facilities are counted on the day of certification inspection.

## Resident population

See Appendix II, Population.

## Rural

See Appendix II, Urbanization.

Self-assessment of health—See Appendix II, Health status, respondent-assessed.

## Serious psychological distress

The K6 mental health screening instrument is a measure of psychological distress associated with unspecified but potentially diagnosable mental illness that may result in a higher risk for disability and higher utilization of health services. In the National Health Interview Survey (NHIS), the K6 questions were asked of adults aged 18 and over. The K6 is designed to identify persons with serious psychological distress, using as few questions as possible. The six items included in the K6 are:

During the past 30 days, how often did you feel:

- So sad that nothing could cheer you up?
- Nervous?
- Restless or fidgety?
- Hopeless?
- That everything was an effort?
- Worthless?

Possible answers are “All of the time” (4 points), “Most of the time” (3 points), “Some of the time” (2 points), “A little of the time” (1 point), and “None of the time” (0 points.)

To score the K6, the points are added together, yielding a possible total of 0-24 points. A threshold of 13 points or more is used to define serious psychological distress. Persons answering “Some of the time” to all six questions would not reach the threshold for serious psychological distress because they would need to answer “Most of the time” to at least one item to achieve a score of 13. Only respondents who answered all six psychological distress questions would have a computed K6 score for analysis. The version of the K6 used in NHIS provides 1-month prevalence rates because the reference period is the past 30 days. For more information, see: Kessler RC, Barker PR, Colpe LJ, Epstein JF, Gfroerer JC, Hiripi E, et al. Screening for serious mental illness in the general population. Arch Gen Psychiatry 60(2):184-9. 2003. (Also see Appendix II, Functional limitation.)

Starting in 2013, the K6 questions were moved to the adult selected items section of the Sample Adult questionnaire. Observed differences between 2012 and earlier estimates and 2013 and later estimates may be partially or fully attributable to this change in question placement within the Sample Adult questionnaire.

## Short-stay hospital

See Appendix II, Hospital.

## Skilled nursing facility

See Appendix II, Nursing home.

## Smoker

See Appendix II, Tobacco use.

## Special hospital

See Appendix II, Hospital.

## Substance use

Refers to the use of selected substances, including alcohol, tobacco products, drugs, inhalants, and other substances that can be consumed, inhaled, injected, or otherwise absorbed into the body with possible dependence and other detrimental effects. (Also see Appendix II, Alcohol consumption; Illicit drug use; Tobacco use.)

Monitoring the Future (MTF) Study—Collects information on the use of selected substances by using self-completed questionnaires in a school-based survey of secondary school students. MTF has tracked 12th graders’ illicit drug use and attitudes toward drugs since 1975. In 1991, 8th and 10th graders were added to the study. The survey includes questions on abuse of substances including (but not limited to) marijuana, inhalants, other illegal drugs, alcohol, and tobacco products. (Also see Appendix I, Monitoring the Future [MTF] Study.)

National Survey on Drug Use and Health (NSDUH)—Conducts in-person, computer-assisted interviews of a sample of individuals aged 12 and over at their place of residence. For illicit drug use, alcohol use, and tobacco use, information is collected about use in the lifetime, past year, and past month. However, only estimates of use in the past month are presented in Health, United States. For illicit drug use, respondents in NSDUH are asked about use of marijuana or hashish, cocaine (including crack), inhalants, hallucinogens, heroin, and misuse of prescription-type psychotherapeutic drugs (pain relievers, tranquilizers, stimulants, and sedatives). A series of questions is asked about each substance: “Have you ever, even once, used [substance]?,” and “How long has it been since you last used [substance]?” Numerous probes and checks are included in the computer-assisted interview system. Starting in 2013, information about marijuana use that was recommended by a doctor or other health care professional has been collected; however, any reported marijuana use is classified as illicit drug use. Starting in 2015, changes in measurement for 7 of the 10 illicit drug categories—hallucinogens, inhalants, methamphetamine, and the misuse of prescription pain relievers, tranquilizers, stimulants, and sedatives—may affect their comparability with the estimates of these illicit drugs and any illicit drug use produced prior to 2015. Additionally, prescription psychotherapeutic subtypes were revised in 2016; therefore, data on codeine products prior to 2016 cannot be compared with those from 2016 onward. (Also see Appendix I, National Survey on Drug Use and Health [NSDUH].)

## Suicidal ideation

Refers to having thoughts of suicide or of taking action to end one’s own life. Suicidal ideation includes all thoughts of suicide, both when the thoughts include a plan to commit suicide and when they do not include a plan. Suicidal ideation is measured in the Youth Risk Behavior Surveillance System by the following three questions: “During the past 12 months, did you ever seriously consider attempting suicide?,” “During the past 12 months, how many times did you actually attempt suicide?,” and “If you attempted suicide during the past 12 months, did any attempt result in an injury, poisoning, or overdose that had to be treated by a doctor or nurse?” For more information, see: https://www.cdc.gov/HealthyYouth/yrbs/index.htm.

## Surgery

See Appendix II, Outpatient surgery; Procedure.

## Surgical specialty

See Appendix II, Physician specialty.

## Tobacco use

Tobacco products encompass varieties of products including: cigarettes, cigarette tobacco, roll-your-own tobacco, smokeless tobacco, electronic cigarettes, cigars, hookahs, pipe tobacco, nicotine gels, and dissolvables. Vapes, vaporizers, vape pens, hookah pens, electronic cigarettes (e-cigarettes or e-cigs), and e-pipes are some of the many terms used to describe electronic nicotine delivery systems (ENDS). ENDS are noncombustible tobacco products. Cigars include premium cigars, little filtered cigars, and cigarillos. Use of tobacco products is measured differently by the data systems used in Health, United States.

Monitoring the Future (MTF) Study—Collects information on the use of selected substances by using self-completed questionnaires in a school-based survey of secondary school students. Information on current cigarette smoking was obtained for 12th graders (starting in 1975) and for 8th and 10th graders (starting in 1991), based on the following question: “How frequently have you smoked cigarettes during the past 30 days?” Information on e-cigarette use was obtained for 8th, 10th, and 12th graders (starting in 2014), based on the following question: “During the last 30 days, on how many days (if any), have you used electronic cigarettes (e-cigarettes)?” Any amount of use reported in the past 30 days was classified as recent use of that tobacco product.

National Health Interview Survey (NHIS)—Information about cigarette smoking is obtained for adults aged 18 and over. From 1965 through 1991, the basic cigarette smoking status questions consisted of two parts: (1) “Have you smoked at least 100 cigarettes during your entire life?” If yes, “Do you smoke now?”

In 1991, a transition to a new measure of smoking status was initiated. For the first time, NHIS distinguished smokers who smoked daily from those who smoked less often than daily. Respondents were first asked, “Have you smoked at least 100 cigarettes during your entire life?” If yes, “Do you smoke now?” To those who said “yes” to the question about current smoking, the question was asked, “Do you smoke every day or some days?” For those who said “no” to the current smoking status question, the question was asked, “Do you smoke some days or not at all?” This additional follow-up resulted in the classification of persons as “someday smokers” who would otherwise have been considered former smokers, since they initially said that they did not smoke now.

In 1992, the transition to the current set of questions occurred. The NHIS Cancer Supplement consisted of two separate questionnaires, each asked of a representative sample of the U.S. civilian noninstitutionalized adult population aged 18 years and over. The Cancer Control questionnaire contained the same set of questions asked in 1991, while the Cancer Epidemiology questionnaire asked “Have you smoked at least 100 cigarettes during your entire life?” If yes, “Do you NOW smoke cigarettes every day, some days, or not at all?” The inclusion of both sets of questions in the same year allowed for evaluation of the impact of the question change on population prevalence The revised current smoking status question was estimated to have resulted in an increase in smoking prevalence of about 1% as a result of capturing smoking among persons who would otherwise have been classified as nonsmokers with the original question. The estimates for 1992 shown in Health, United States combine data collected using both the traditional and revised questions. Estimates for 1993 and beyond use the revised questions.

In 1993-1995, estimates of cigarette smoking prevalence were based on a half-sample. Smoking data were not collected in 1996. Starting in 1997, smoking data were collected in the Sample Adult questionnaire. Starting in 2014, questions were added to NHIS on the use of e-cigarettes; however, estimates on e-cigarette use from NHIS are not presented in Health, United States. For more information on survey methodology and sample sizes pertaining to NHIS cigarette smoking data, see the NHIS “Adult Tobacco Use Information” website at: https://www.cdc.gov/nchs/nhis/tobacco.htm.

National Survey on Drug Use and Health (NSDUH)—Conducts in-person, computer-assisted interviews of a sample of individuals aged 12 and over at their place of residence. Information on current cigarette smoking is obtained based on the following question: “Now think about the past 30 days—that is, from [DATE] up to and including today. During the past 30 days, have you smoked part or all of a cigarette?”

To measure current use of any tobacco products, respondents were asked about the use of each tobacco product on 1 or more days in the past 30 days, including: smokeless tobacco (such as snuff, dip, chewing tobacco, or snus), cigars, or pipe tobacco. Any amount of use reported in the past 30 days was classified as recent use of that tobacco product. Electronic cigarette use was not considered in the definition of current cigarette smoking or any use of tobacco products.

National Youth Tobacco Survey (NYTS)—An annual school-based survey of U.S. middle and high school students that collects data on tobacco use and tobacco-related attitudes, beliefs, and influences. Students in grades 6-12 were asked questions about the use of a variety of tobacco products on 1 or more days during the past 30 days. Tobacco products include: cigarettes; cigars, cigarillos, or little cigars; chewing tobacco, snuff, or dip; e-cigarettes; hookah or water pipe; roll-your-own cigarettes; pipe filled with tobacco (not water pipe); snus; dissolvable tobacco products; and bidis (small brown cigarettes wrapped in a leaf). Any amount of use reported in the past 30 days was classified as recent use of that tobacco product.

## Uninsured

Broadly, persons are considered uninsured if they do not have coverage under private health insurance, Medicare, Medicaid, public assistance (through 1996), Children’s Health Insurance Program (CHIP), a state-sponsored or other government-sponsored plan or program, or a military health plan. Because of differences in methodology, question wording, and recall period, estimates from different sources may vary and are not directly comparable. For more information, see: U.S. Census Bureau. Health insurance measurement: Differences by data source. Available from: https://www2.census.gov/programs-surveys/demo/visualizations/p60/257/health_insurance_measurement.pdf.

American Community Survey (ACS)—In ACS, persons are considered uninsured if they do not have coverage through private health insurance, Medicare, Medicaid, TRICARE or other military health care, veteran’s coverage through the Veteran’s Administration, or other government insurance. Persons with only Indian Health Service coverage are considered uninsured The questions on health insurance are administered throughout the year and ask about current health insurance coverage as of the day of the interview.

National Health Interview Survey (NHIS)—In NHIS, the uninsured are persons who do not have coverage under private health insurance, Medicare, Medicaid, public assistance (through 1996), CHIP, a state-sponsored health plan, other government-sponsored programs, or a military health plan. Persons with only Indian Health Service coverage are considered uninsured. Estimates for the uninsured are shown only for the population under age 65. Estimates of the percentage of persons who are uninsured based on NHIS may differ slightly from those based on the March Current Population Survey or the American Community Survey because of differences in survey questions, recall period, and other aspects of survey methodology.

Survey respondents may be covered by health insurance at the time of interview but may have experienced one or more lapses in coverage during the year prior to interview. Starting with Health, United States, 2006, NHIS estimates for people with health insurance coverage for all 12 months prior to interview, for those who were uninsured for any period up to 12 months, and for those who were uninsured for more than 12 months were added as stub variables to selected tables. (Also see Appendix II, Health insurance coverage.)

## Urbanization

The degree of urban (city-like) character of a particular geographic area Urbanization can be measured in a variety of ways. In Health, United States, the two measures currently used to categorize counties by urbanization level are the Office of Management and Budget’s (OMB) metropolitan and micropolitan statistical area classification and the 2013 NCHS (National Center for Health Statistics) Urban-Rural Classification Scheme for Counties. For more information on the OMB classification of counties, see Appendix II, Metropolitan statistical area (MSA); Micropolitan statistical area.

The 2013 Urban-Rural Classification Scheme is based on the February 2013 OMB delineation of MSAs and micropolitan statistical areas, 2012 postcensal estimates of county and place population, and county-level data on selected settlement density, socioeconomic, and demographic variables from Census 2010. This is an updated version of NCHS’ earlier scheme, the 2006 NCHS Urban-Rural Classification Scheme for Counties. The six categories of the NCHS scheme are large central metro (inner-city counties of MSAs of 1 million or more population), large fringe metro (suburban counties of MSAs of 1 million or more population), medium metro (counties of MSAs of 250,000-999,999 population), small metro (counties of MSAs with less than 250,000 population), nonmetropolitan micropolitan statistical areas, and nonmetropolitan noncore. For more information on the classification scheme, see: https://www.cdc.gov/nchs/data_access/urban_rural.htm.

## Usual source of care

Measured in the National Health Interview Survey (NHIS) in 1993 and 1994 by asking the respondent, “Is there a particular person or place that [person] usually goes to when [person] is sick or needs advice about [person’s] health?” In the 1995 and 1996 NHIS, the respondent was asked, “Is there one doctor, person, or place that [person] usually goes to when [person] is sick or needs advice about health?” Starting in 1997, the respondent was asked, “Is there a place that you USUALLY go to when you are sick or need advice about your health?” In a sample child interview, the question was asked “Is there a place that [child] USUALLY goes when [he/she] is sick or you need advice about [his/her] health?” Persons who report the emergency department as their usual source of care are defined in Health, United States as having no usual source of care.

## Vaccination

Also called immunizations, work by stimulating the immune system—the natural disease-fighting system of the body. A healthy immune system is able to recognize invading bacteria and viruses and produce substances (antibodies) to destroy or disable these invaders. Vaccinations prepare the immune system to ward off a disease. In addition to the initial immunization process, the effectiveness of some immunizations can be improved by periodic repeat injections or “boosters.” Vaccines are among the most successful and cost-effective public health tools available for reducing morbidity and mortality from vaccine-preventable diseases. For a comprehensive list of vaccine-preventable diseases, see: https://www.cdc.gov/vaccines/vpd/vaccines-list.html, and https://www.cdc.gov/vaccines/spec-grps.html.

The currently recommended childhood vaccination schedule includes vaccines that prevent infectious diseases, including hepatitis A and B, diphtheria, tetanus toxoids, acellular pertussis (whooping cough), measles, mumps, rubella (German measles), polio, varicella (chicken pox), and some forms of meningitis (HIB), influenza, and pneumococcal disease. In February 2006, a rotavirus vaccine (RotaTeq) was licensed for use in U.S. infants.

A quadrivalent vaccine that protects against the four types of human papillomavirus (HPV) that cause most cervical cancers and genital warts was marketed starting in 2006 and is now available for both females and males. In 2006, the vaccine was recommended for females aged 11 and 12 and females aged 13-26 who have not yet been vaccinated or completed the vaccine series. In 2011, HPV vaccination also was recommended for males aged 11 and 12. More information is available from: https://www.cdc.gov/mmwr/preview/mmwrhtml/mm6050a3.htm.

In addition to keeping current with the vaccines listed above and annual influenza vaccination, some additional vaccinations are recommended for older adults, persons with specific health conditions, or health care workers who are likely to be exposed to infectious persons. For example, herpes zoster vaccination is recommended for adults aged 60 and over, and pneumococcal vaccination is recommended for adults aged 65 and over and persons with specific health conditions. For a full discussion of recommended vaccination schedules by age and population, see the Centers for Disease Control and Prevention’s (CDC’s) vaccination and immunization website at: https://www.cdc.gov/vaccines/schedules/index.html.

Influenza vaccination—In the National Health Interview Survey, questions concerning influenza vaccination differed slightly across the survey years. Prior to September 2003, respondents were asked, “During the past 12 months, have you had a flu shot? A flu shot is usually given in the fall and protects against influenza for the flu season.” Starting in September 2003, respondents were asked about influenza vaccination by nasal spray (sometimes called by the brand name FluMist) during the past 12 months, in addition to the question regarding the flu shot. Starting with 2005 data, receipt of nasal spray or a flu shot was included in the calculation of influenza vaccination estimates presented in Health, United States. Starting with 2010 data, additional questions were asked about the receipt of the H1N1 flu shot and spray, including month and year received. These H1N1 questions and the original seasonal flu questions were asked only in Quarters 1 and 2 and the first several weeks of Quarter 3. Starting August 11, 2010, revised flu vaccination questions replaced all flu vaccination questions fielded earlier in 2010 and were used in 2011. The revised questions reflect the introduction of a new combined flu vaccination that protects against both the seasonal and H1N1 strains. For more information regarding the influenza questions that were introduced in 2010, see: ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Dataset_Documentation/NHIS/2010/srvydesc.pdf.

The prevalence of influenza vaccination during the past 12 months may differ from season-specific coverage, and estimates from different data sources may differ (additional estimates are available from: https://www.cdc.gov/flu/fluvaxview/). See: Lu PJ, Santibanez TA, Williams WW, Zhang J, Ding H, Bryan L, et al. Surveillance of influenza vaccination coverage—United States, 2007-08 through 2011-12 influenza seasons. MMWR Surveill Summ 62(4):1-28. 2013. Available from: https://www.cdc.gov/mmwr/preview/mmwrhtml/ss6204a1.htm?s_cid=ss6204a1_w.

The recommendations of the Advisory Committee on Immunization Practices regarding who should receive an influenza vaccination have changed over the years, and changes in coverage estimates may reflect changes in recommendations. An influenza vaccine shortage occurred during the 2004-2005 influenza season. Delays in the availability of influenza shots also occurred in fall 2000, and to a lesser extent, in fall 2001.

Pneumococcal vaccination—In the National Health Interview Survey, questions concerning pneumococcal vaccination differed slightly across the survey years. Prior to 1999, respondents were asked, “Have you EVER had a pneumonia vaccination? This shot is usually given only once in a person’s lifetime and is different from the flu shot.” Starting in 1999, respondents were asked, “Have you EVER had a pneumonia vaccination, sometimes called a pneumonia shot? This shot is usually given only once in a person’s lifetime and is different from the flu shot.” Starting in 2001, respondents were asked, “Have you EVER had a pneumonia shot? This shot is usually given only once or twice in a person’s lifetime and is different from the flu shot. It is also called the pneumococcal vaccine “

## Wages and salaries

See Appendix II, Employer costs for employee compensation.

## Years of potential life lost (YPLL)

A measure of premature mortality. Starting with Health, United States, 1996, YPLL has been presented for persons under age 75 because the average life expectancy in the United States is over 75 years. YPLL-75 is calculated using the following eight age groups: under 1, 1-14, 15-24, 25-34, 35-44, 45-54, 55-64, and 65-74. The number of deaths for each age group is multiplied by years of life lost, calculated as the difference between age 75 years and the midpoint of the age group. For the eight age groups, the midpoints are 0.5, 7.5, 19.5, 29.5, 39.5, 49.5, 59.5, and 69. 5 years, respectively. For example, the death of a person aged 15-24 counts as 55.5 years of life lost. YPLL is derived by summing years of life lost over all age groups. In Health, United States, 1995 and earlier editions, YPLL was presented for persons under age 65. For more information, see: Centers for Disease Control and Prevention. Premature mortality in the United States: Public health issues in the use of years of potential life lost. MMWR Suppl 35(SS-02):1S-11S. 1986. Available from: https://www.cdc.gov/mmwr/preview/mmwrhtml/00001773.htm.