# Highlights

This Highlights section includes data from the four major areas included in the report: health status and determinants, utilization of health resources, health care resources, and health care expenditures and payers. As Health, United States enters its 40th year of reporting on the health of the nation, this year’s Highlights section presents trends in health from 1975 or the earliest year possible, given data availability and comparability issues. The Highlights focus on both trends and current data on topics of public health interest and illustrate the breadth of material included in Health, United States. Each highlight includes a reference to the detailed trend table or figure where definitions of terms and additional data can be obtained.

## Health Status and Determinants

### Life Expectancy and Mortality

Between 1975 and 2015, life expectancy at birth increased from 72.6 to 78.8 years for the total U.S. population. For males, life expectancy increased from 68.8 years in 1975 to 76.3 years in 2015, and for females, life expectancy increased from 76.6 years in 1975 to 81.2 years in 2015 (Table 15).

Life expectancy at birth decreased 0.1 years overall between 2014 and 2015. For males, life expectancy declined 0.2 years from 76.5 years in 2014 to 76.3 years in 2015, and for females, life expectancy decreased 0.1 years, from 81.3 years in 2014 to 81.2 years in 2015 (Table 15).

Between 1975 and 2015, life expectancy at birth increased more for the black than for the white population, thereby narrowing the gap in life expectancy between these two racial groups. In 1975, life expectancy at birth for the white population was 6.6 years longer than for the black population; by 2015, the difference had narrowed to 3.5 years (Figure 6).

Between 2014 and 2015, life expectancy at birth was stable at 82.0 years for Hispanic persons, decreased 0.2 years to 78.7 years for non-Hispanic white persons, and decreased 0.2 years to 75.1 years for non-Hispanic black persons (Table 15).

Between 1975 and 2015, the infant mortality rate decreased 63%, from 16.07 to 5.90 deaths per 1,000 live births and the neonatal mortality rate (among infants under age 28 days) decreased 66%, from 11.58 to 3.93. Between 1975 and 2015, the postneonatal mortality rate (among infants aged 28 days through 11 months) decreased 56%, from 4.49 to 1.96 (Figure 7).

Despite declines in infant mortality for all racial and ethnic groups, infants of non-Hispanic black mothers (10.93 infant deaths per 1,000 live births) had the highest infant mortality rates compared with the other racial and ethnic groups in 2014 (Figure 7 and Table 10).

Between 1975 and 2015, the age-adjusted heart disease death rate decreased 61% from 431.2 to 168.5 deaths per 100,000 population; and the age-adjusted cancer death rate decreased 21% from 200.1 to 158.5 deaths per 100,000 population. Throughout 1975–2015, heart disease and cancer were the first and second leading causes of death. In 2015, these two causes accounted for 45% of all deaths (Figure 8 and Table 19).

The age-adjusted drug poisoning death rate involving opioid analgesics increased from 1.4 to 5.4 deaths per 100,000 population between 1999 and 2010, decreased to 5.1 in 2012 and 2013, then increased to 5.9 in 2014, and to 7.0 in 2015. The age-adjusted drug poisoning death rate involving heroin doubled from 0.7 to 1.4 deaths per 100,000 resident population between 1999 and 2011 and then continued to increase to 4.1 in 2015 (Table 27).

In 2015, the 10 leading causes of death were heart disease, cancer, chronic lower respiratory diseases, unintentional injuries, stroke, Alzheimer’s disease, diabetes, influenza and pneumonia, kidney disease, and suicide. These 10 causes of death accounted for 74% of the 2.7 million deaths in 2015 (Figure 8 and Table 19).

Between 2014 and 2015, age-adjusted death rates increased for eight of the ten leading causes. The only decrease in age-adjusted death rates among the 10 leading causes of death between 2014 and 2015 was for cancer; the rate for influenza and pneumonia did not change significantly (Table 17).

Between 2014 and 2015, the age-adjusted suicide death rate increased 2%, from 13.0 to 13.3 deaths per 100,000 resident population. Among adolescents and adults aged 15–24, suicide death rates increased 8% between 2014 and 2015 (Table 30).

### Fertility and Natality

Between 1975 and 2015, the birth rate among teenagers aged 15–19 fell 60%, from 55.6 to 22.3 live births per 1,000 females—a record low for the United States (Figure 9).

In 1975, 7.38% of infants were low-birthweight (weighing less than 2,500 grams [5.5 pounds] at birth) compared with 8.07% in 2015. Low-birthweight was more common among infants of non-Hispanic black mothers (13.35%) and Puerto Rican mothers (9.42%) than among infants of mothers in other racial and ethnic groups in 2015 (Table 5).

### Health Risk Factors for the Noninstitutionalized Population

#### Children

From 1988–1994 to 2003–2004, the percentage of children and adolescents aged 2–19 with obesity increased from 10.0% to 17.1%, and then was stable from 2003–2004 to 2013–2014. The percentage of children and adolescents with obesity was 17.2% in 2013–2014 (Figure 11).

In 2015, 4.2% of adolescents aged 12–17 reported smoking cigarettes in the past month. Smoking prevalence has declined since 2002, when 13.0% of adolescents reported smoking cigarettes in the past month (Table 50).

In 2015, e-cigarette use in the past month was reported by 16.2% of 12th graders, 14.0% of 10th graders, and 9.5% of 8th graders (Table 51).

#### Adults

Between 1988–1994 and 2013–2014, the percentage of adults aged 20 and over with Grade 1 obesity (a body mass index [BMI] of 30.0–34.9) increased from 14.8% to 20.7%. Those with Grade 2 obesity (BMI of 35.0–39.9) rose from 5.2% to 9.5%, and those with Grade 3 obesity (BMI of 40 or higher) increased from 2.9% to 7.6% (percentages are age-adjusted) (Figure 11).

Between 1974 and 2015, the age-adjusted prevalence of current cigarette smoking declined from 36.9% to 15.6% among persons aged 25 and over. Current cigarette smoking declined as educational attainment increased, from 25.6% of adults aged 25 and over without a high school diploma or GED to 5.9% of those with a Bachelor’s degree or higher in 2015 (Figure 10 and Table 48).

### Measures of Health and Disease Prevalence for the Noninstitutionalized Population

Between 1997–1999 and 2013–2015, the percentage of children and adolescents under age 18 with a food allergy increased from 3.4% to 5.6%. During the same period, the percentage of children and adolescents under age 18 with a skin allergy increased from 7.4% to 11.8% (Table 35).

For children and adolescents aged 5–19 living below the federal poverty level, the percentage with untreated dental caries declined steadily from 39.0% in 1988–1994 to 24.7% in 2011–2014 (Figure 12).

Between 1997–1999 and 2013–2015, the percentage of children and adolescents aged 5–17 diagnosed with attention deficit/hyperactivity disorder increased from 6.5% to 10.4% (Table 35).

From 1988–1994 to 2011–2014, the age-adjusted percentage of adults aged 20 and over with hypertension who had uncontrolled high blood pressure decreased for both men (83.2% to 58.1%) and women (68.5% to 45.5%). Throughout the period, among those with hypertension, men had a higher percentage with uncontrolled blood pressure than women (Figure 14 and Table 54).

Between 1988–1994 and 2011–2014, the age-adjusted prevalence of total diabetes among adults aged 20 and over increased from 8.8% to 11.9%. In both time periods, the age-adjusted prevalence of total diabetes was higher among non-Hispanic black and Mexican origin adults compared with non-Hispanic white adults (Figure 13 and Table 40).

## Utilization of Health Resources for the Noninstitutionalized Population

### Use of Health Care Services

Between 1997 and 2015, the percentage of persons who had no health care visits in the past 12 months decreased from 16.5% to 14.6%. In 2015, 7.9% of children and adolescents under age 18, 23.3% of adults aged 18–44, 13.7% of those aged 45–64, and 5.5% of adults aged 65 and over had no health care visits in the past 12 months (Table 65).

Between 1975 and 2015, the percentage of males and females under age 75 with an overnight hospital stay in the prior 12 months declined, while remaining stable among those aged 75 and over. Hospitalization use generally increased with age, from 2.1% of boys and girls aged under 18 to 20.3% of men and 17.7% of women aged 75 and over in 2015 (Figure 18).

Between 1988–1994 and 2013–2014, the percent of adults who had taken at least one prescription drug in the past 30 days increased for adults aged 18–44, adults aged 45–64, and adults aged 65 and over. In 2013–2014, 36.5% of adults aged 18–44 years, 69.6% of adults aged 45–64 years, and 90.8% of adults aged 65 years and over had taken at least one prescription drug (Figure 15).

Between 1997 and 2015, the percentage of persons aged 2 and over who had a dental visit in the past year increased from 65.1% to 68.2%. In 2015, 84.7% of children aged 2–17 years, 64.0% of adults aged 18–64, and 62.7% of adults aged 65 and over had visited a dentist in the past year (Table 78).

### Use of Preventive Medical Care Services for the Noninstitutionalized Population

Between 2008 and 2015, receipt of the full series of human papillomavirus (HPV) vaccine for adolescents aged 13–17 increased among females from 17.9% to 41.9% (Table 67). The HPV vaccine was first recommended for adolescent males in October 2011; receipt of the full series for males aged 13–17 increased from 1.3% in 2011 to 28.1% in 2015.

Between 2010 and 2015, the percentage of adults aged 18 and over who had received an influenza vaccination in the past 12 months increased from 35.8% to 43.2%. In 2015, influenza vaccination increased with age, with 30.9% of those aged 18–44, 45.1% of those aged 45–64, and 69.1% of those aged 65 and over reporting an influenza vaccination in the past 12 months (Table 68).

Between 2000 and 2015, the percent of adults aged 50–75 with a colorectal cancer test or procedure approximately doubled for each of the four racial and ethnic groups. In 2015, 52.1% of non-Hispanic Asian and 47.4% of Hispanic adults aged 50–75 had a colorectal cancer test, compared with 60.3% of non-Hispanic black and 65.6% of non-Hispanic white adults aged 50–75 (Figure 19).

### Difficulty Accessing Needed Medical Care Due to Cost for the Noninstitutionalized Population

The percentage of adults aged 18–64 who reported delaying or not receiving needed medical care due to cost increased from 10.7% in 1997 to 14.7% in 2010 and then declined to 9.8% in 2015 (Table 63).

## Health Care Resources

Between 2001 and 2015, the number of professionally active dentists in the United States increased from 57.32 to 60.89 dentists per 100,000 civilian population. In 2015, the number of dentists per 100,000 population ranged from 40.93 in Arkansas to 89.85 in the District of Columbia (Table 86).

The average length of community hospital stays fell from 7.7 days in 1975 to 5.5 days in 2014. The occupancy rate for community hospitals declined from 75.0% in 1975 to 64.8% in 1985 and then to 62.8% in 2014 (Figure 20).

Between 1995 and 2015, the U.S. nursing home occupancy rate decreased from 84.5% to 80.3%. In 2015, nursing home occupancy rates were highest in North Dakota (92.7%), the District of Columbia (91.8%), Rhode Island (91.4%), and South Dakota (91.4%). The lowest occupancy rates in 2015 were in Oregon (60.1%), Utah (63.9%), Indiana (64.3%), and Idaho (64.9%) (Table 92).

## Health Care Expenditures and Payers

### Health Care Expenditures

Between 1975 and 2015, national health expenditures as a percent of gross domestic product (GDP) increased from 7.9% to 17.8% (Table 93).

Between 1975 and 2015, the percentage of personal health care expenditures for hospital care decreased from 45.3% to 38.1%; the percentage of expenditures for prescription drugs increased from 7.1% to 11.9%; the percentage of expenditures for nursing care facilities and continuing care retirement communities decreased from 7.1% to 5.8%; and the percentage of expenditures for physician and clinical services remained stable (22.4%–23.4%) (Table 94).

Between 2000 and 2014, the average inflation-adjusted cost for the entire hospitalization involving a heart valve procedure increased from $44,609 to $51,896; a coronary artery bypass graft procedure increased from $32,520 to $41,932; cardiac pacemaker or defibrillator insertion, revision, replacement, or removal increased from $28,757 to $34,974; and spinal fusion increased from $18,119 to $28,949 (Table 96).

### Health Care Payers

Between 1975 and 2015, the share of all personal health care expenditures paid by private insurance increased from 24.5% to 34.8%; by Medicare increased from 13.8% to 22.3%; and by Medicaid increased from 11.3% to 17.9%. The share paid by consumers out-of-pocket decreased from 32.9% to 12.4% during the same period (Figure 23 and Table 95).

Between 1986 and 2014, the share of mental health expenditures paid for inpatient care decreased from 41% to 16%; residential treatment decreased from 22% to 12%; outpatient treatment increased from 24% to 35%; and the share paid for retail prescription drugs increased from 8% to 27% (Figure 24).

Between 1986 and 2014, the share of substance use disorder expenditures paid for inpatient care decreased from 50% to 19%; outpatient treatment increased from 27% to 40%; residential treatment increased from 17% to 27%; and the share paid for retail prescription drugs increased from less than 1% to 5% (Figure 24).

### Health Insurance Coverage for the Noninstitutionalized Population

Between 1978 and September 2016 (preliminary estimates), the percentage of children under age 18 with Medicaid coverage increased from 11.3% to 39.2% and the percentage of children who were uninsured decreased from 12.0% to 5.0% (Martinez ME, Zammitti EP, Cohen RA. Health insurance coverage: Early release of estimates from the National Health Interview Survey, January–September 2016. NCHS; 2017. Available from: https://www.cdc.gov/nchs/data/nhis/earlyrelease/insur201702.pdf; Figure 26; and unpublished data).

The percentage of adults aged 18–64 who were uninsured increased from 11.9% in 1978 to over 18% by the mid-1990s before climbing to more than 20% in the early years of the 2010 decade. The percentage then decreased to 12.3% in September 2016 (preliminary data) (Martinez ME, Zammitti EP, Cohen RA. Health insurance coverage: Early release of estimates from the National Health Interview Survey, January–September 2016. NCHS; 2017. Available from: https://www.cdc.gov/nchs/data/nhis/earlyrelease/insur201702.pdf; Figure 27).

A provision of the ACA requires insurers to extend dependent coverage on a family plan until age 26, effective in 2010. The percentage of adults aged 19–25 who were uninsured decreased from 33.8% in 2010 to 16.0% in 2015 (Table 105).

During January–September 2016 (preliminary data), 14.6% of adults aged 19–25 were uninsured (Martinez ME, Zammitti EP, Cohen RA. Health insurance coverage: Early release of estimates from the National Health Interview Survey, January–September 2016. NCHS; 2017. Available from: https://www.cdc.gov/nchs/data/nhis/earlyrelease/insur201702.pdf).

In 2015, Massachusetts (3.2%), the District of Columbia (4.0%), Hawaii (4.5%), and Vermont (5.0%) had the lowest percentages of persons uninsured (i.e., without public or private coverage) among those under age 65, while Florida (16.2%), Oklahoma (16.5%), and Texas (19.0%) had the highest percentages of persons uninsured (Table 114).