# Acknowledgments

Overall responsibility for planning and coordinating the content of this volume rested with the National Center for Health Statistics’ (NCHS) Office of Analysis and Epidemiology, under the direction of Julia S. Holmes and Irma E. Arispe.

Production of Health, United States, 2016 was managed by Sheila J. Franco, Virginia M. Freid, Julia S. Holmes, and Hashini S. Khajuria. Preparation of the volume, including highlights, trend tables, appendixes, and index, was completed by Shilpa Bengeri, Mary Ann Bush, La-Tonya D. Curl, Anne K. Driscoll, Catherine R. Duran, Sheila J. Franco, Virginia M. Freid, Nancy Han, Hashini S. Khajuria, Ji-Eun Kim, Florence Lee, Xianfen Li, Anita L. Powell, Ilene B. Rosen, and Ashley M. Woodall. Administrative and word processing assistance was provided by Lillie C. Featherstone.

Production of the Chartbook was managed by Sheila J. Franco and Virginia M. Freid. Data, analysis, and text for specific charts were provided by Shilpa Bengeri, Mary Ann Bush, La-Tonya D. Curl, Anne K. Driscoll, Catherine R. Duran, Sheila J. Franco, Virginia M. Freid, Nancy Han, Hashini S. Khajuria, Ji-Eun Kim, Florence Lee, Xianfen Li, Diane M. Makuc, and Ashley M. Woodall.

Publication assistance was provided by CDC/OPHSS/NCHS/OD/Office of Information Services (OIS) and Office of Information Technology (OIT). Cover design was provided by Sarah Hinkle. Printing was managed by Nathanael Brown (CDC/OD/OADC). Publication production was performed under contract with Karna, LLC. Electronic access through the NCHS website was provided by Shilpa Bengeri, Christine J. Brown (CDC/OPHSS/NCHS/OD/OMO), La-Tonya D. Curl, Virginia M. Freid, Elom L. Lawson, Florence Lee, Anthony Lipphardt, Anita L. Powell, Ilene B. Rosen, Brian Tsai (CDC/OPHSS/NCHS/OD), and Ashley M. Woodall.

Data and technical assistance were provided by staff of the following NCHS organizations: Division of Health Care Statistics: Jill Ashman, Lauren Harris-Kojetin, Pinyao Rui, Susan M. Schappert, Manisha Sengupta, and Victor V. Shigaev; Division of Health and Nutrition Examination Surveys: Namanjeet Ahluwalia, Margaret D. Carroll, Mark S. Eberhardt, Eleanor B. Fleming, Qiuping Gu, Brian K. Kit, Cynthia L. Ogden, and Ryne Paulose-Ram; Division of Health Interview Statistics: Veronica Benson, Debra Blackwell, Barbara Bloom, Robin A. Cohen, Jacqueline Lucas, Tina Norris, Jeannine Schiller, Charlotte Schoenborn, Maria Villarroel, Brian Ward, and Emily Zammitti; Division of Vital Statistics: Robert N. Anderson, Joyce A. Arbertha, Elizabeth Arias, Amy M. Branum, Anjani Chandra, Sally C. Curtin, Kimberly Daniels, Anne K. Driscoll, Elizabeth Gregory, Annie Liu, Joyce A. Martin, T.J. Mathews, Arialdi M. Miniño, Steven J. Steimel, and Margaret Warner; Office of Analysis and Epidemiology: Holly Hedegaard, Deborah D. Ingram, Ellen A. Kramarow, Laura A. Pratt, and Cheryl V. Rose; Office of the Center Director: Juan Albertorio and Francis C. Notzon; and Office of Research and Methodology: Meena Khare.

Additional data and technical assistance were provided by the following organizations of the Centers for Disease Control and Prevention (CDC): National Center for Chronic Disease Prevention and Health Promotion: Tara Jatlaoui; National Center for HIV/AIDS, Viral Hepatitis, STD, and TB Prevention: Jim Braxton, Lori Elmore, Anna Satcher Johnson, Sarah Kidd, Jennifer Ludovic, Rodney Presley, Elizabeth Torrone, Hillard Weinstock, and the Surveillance and Data Management Branch; National Center for Immunization and Respiratory Diseases: Laurie D. Elam-Evans, Holly A. Hill, James Singleton, and David Yankey; Office of Public Health Scientific Services, Center for Surveillance, Epidemiology, and Laboratory Services: Ruth Ann Jajosky; by the following organizations within the Department of Health and Human Services: Agency for Healthcare Research and Quality: Kellyn V. Carper and Anne Elixhauser; Centers for Medicare & Medicaid Services: Aaron C. Catlin, Tony Dean, Maria Diacogiannis, Micah B. Hartman, Deborah Kidd, Barbara S. Klees, Jennifer W. Lazio, Anne B. Martin, Debra Reed-Gillette, Joseph F. Regan, Jeffrey S. Silverman, Christopher J. Truffer, and Lekha S. Whittle; National Institutes of Health: Nadia Howlander and Marsha Lopez; Substance Abuse and Mental Health Services Administration: Mitchell Berger, Christopher D. Carroll, Beth Han, and Neil Russell; and by the following governmental and nongovernmental organizations: U.S. Census Bureau: Bernadette Proctor; Bureau of Labor Statistics: Elizabeth A. Ashack, Ryan Farrell, Matt Gunter, Jesus Ranon, and Audrey Watson; Department of Veterans Affairs: Tom Garin and Susan Sullivan; American Association of Colleges of Pharmacy: Nancy T. Nguyen, Danielle A. Taylor, and Jamie N. Taylor; American Association of Colleges of Osteopathic Medicine: Lindsey Jurd; American Association of Colleges of Podiatric Medicine: Moraith G. North; American Dental Association: Adriana R. Menezes and Bradley Munson; Association of American Medical Colleges: Brianna Gunter; Association of Schools and Colleges of Optometry: Joanne C. Zuckerman; Association of Schools & Programs of Public Health: Christine M. Plepys; University of Michigan, Monitoring the Future: Lloyd Johnston and Ginger Maggio; and Cowles Research Group: C. McKeen Cowles.

## Special Acknowledgment

The Health, United States team would like to recognize Virginia (Ginny) M. Freid and Ilene B. Rosen, who recently retired from the National Center for Health Statistics. Ginny contributed to Health, United States for more than 30 years, providing direction and guidance for the report. Her analytical and statistical skills were key to maintaining Health, United States as the gold standard for reporting on health in the United States. Ilene provided meticulous administrative and production support for Health, United States for nearly 10 years, including the critical task of report distribution to key partners and stakeholders. We wish them the very best in their retirement!