# Highlights

This Highlights section presents selected data from the four major areas included in the report: health status and determinants, utilization of health resources, health care resources, and health care expenditures and payers, and from this year's Special Feature on racial and ethnic health disparities. The Highlights focus on topics of public health importance and illustrate the breadth of material included in Health, United States, 2015. The Highlights section generally presents trends for the recent 10-year period or examines information for the most recent data year available. Highlights from the 2015 Special Feature generally present data from 1999 to the most recent year available, or only data from the latest year (see Technical Notes for additional information). Each highlight includes a reference to the detailed trend table or figure where definitions of terms and additional data can be obtained.

## Health Status and Determinants

### Life Expectancy and Mortality

In 2014, life expectancy at birth in the United States for the total population was 78.8 years—76.4 years for males and 81.2 years for females (Table 15).

Between 2004 and 2014, life expectancy at birth increased 1.4 years for males and 1.1 years for females. The gap in life expectancy between males and females narrowed from 5.1 years in 2004 to 4.8 years in 2014 (Table 15).

Between 2004 and 2014, life expectancy at birth increased more for the black than for the white population, thereby narrowing the gap in life expectancy between these two racial groups. In 2004, life expectancy at birth for the white population was 5.2 years longer than for the black population; by 2014, the difference had narrowed to 3.4 years (Table 15).

Between 2013 and 2014, life expectancy at birth increased 0.2 years to 81.8 years for Hispanic persons, decreased 0.1 years to 78.8 years for non-Hispanic white persons, and increased 0.1 years to 75.2 years for non-Hispanic black persons. For males between 2013 and 2014, life expectancy at birth increased 0.1 years to 79.2 years for Hispanic males, remained stable at 76.5 years for non-Hispanic white males, and increased 0.2 years to 72.0 years for non-Hispanic black males. For females between 2013 and 2014, life expectancy at birth increased 0.2 years to 84.0 years for Hispanic females, decreased 0.1 years to 81.1 years for non-Hispanic white females, and remained stable at 78.1 years for non-Hispanic black females (Table 15).

Between 2004 and 2014, the death rate for black men aged 45–54 decreased 28%, from 933.3 to 671.8 deaths per 100,000 resident population, while the death rate for non-Hispanic white men remained stable (511.2 in 2014). Between 2004 and 2014, the death rate for black women aged 45–54 decreased 18%, from 558.9 to 455.8, while the death rate for non-Hispanic white women increased 11%, from 293.4 to 325.5 (Table 21).

Between 2004 and 2014, the infant mortality rate decreased 14%, from 6.79 to 5.82 deaths per 1,000 live births and the neonatal mortality rate (among infants under age 28 days) decreased 13%, from 4.52 to 3.94. Between 2004 and 2014, the postneonatal mortality rate (among infants aged 28 days through 11 months) decreased 17%, from 2.27 to 1.88 (Table 11).

In 2014, the 10 leading causes of death were heart disease, cancer, chronic lower respiratory diseases, unintentional injuries, stroke, Alzheimer's disease, diabetes, influenza and pneumonia, kidney disease, and suicide. These 10 causes of death accounted for 74% of the 2.6 million deaths in 2014 (Table 19).

Between 2004 and 2014, the age-adjusted heart disease death rate decreased 25%, from 221.6 to 167.0 deaths per 100,000 resident population. In 2014, 23% of all deaths in the United States were from heart disease (Tables 19 and 22).

Between 2004 and 2014, the age-adjusted cancer death rate decreased 14%, from 186.8 to 161.2 deaths per 100,000 resident population. In 2014, 23% of all deaths in the United States were from cancer (Tables 19 and 24).

Between 2004 and 2014, the suicide death rate increased 21%, from 11.1 to 13.4 deaths per 100,000 resident population. Among adults aged 45–64, suicide death rates increased 27% between 2004 and 2014 (Table 30).

Between 2004 and 2014, the drug poisoning death rate involving heroin increased more than five times, from 0.6 to 3.3 deaths per 100,000 resident population. In 2014, the drug poisoning death rate involving heroin was highest among those aged 25–34 (8.0), followed by those aged 35–44 (5.9), and those aged 45–54 (4.7) (Table 27).

### Fertility and Natality

Between 2004 and 2014, the birth rate among teenagers aged 15–19 fell 40%, from 40.5 to 24.2 live births per 1,000 females—a record low for the United States (Table 3).

In 2014, 8.00% of infants were low-birthweight (weighing less than 2,500 grams [5.5 pounds] at birth); low-birthweight was more common among non-Hispanic black infants (13.17%) and Puerto Rican infants (9.54%) than among infants in other racial and ethnic groups (Table 5).

### Health Risk Factors for the Noninstitutionalized Population

#### Children

In 2011–2014, the prevalence of children with obesity among those aged 2–5 years was 8.9%, 17.5% among children aged 6–11, and 20.5% among adolescents aged 12–19 (Table 59 and Figure 8).

In 2014, 4.9% of adolescents aged 12–17 reported smoking cigarettes in the past month. Smoking prevalence has declined since 2004, when 11.9% of adolescents reported smoking cigarettes in the past month (Table 50).

#### Adults

In 2014, 20.9% of adults aged 18 and over met the 2008 federal physical activity guidelines for both aerobic activity and muscle strengthening (Table 57).

Between 1999–2002 and 2011–2014, the percentage of adults aged 20 and over with Grade 1 obesity (a body mass index [BMI] of 30.0–34.9) increased from 17.9% to 20.6%. Those with Grade 2 obesity (BMI of 35.0–39.9) rose from 7.6% to 8.8%, and those with Grade 3 obesity (BMI of 40 or higher) increased from 4.9% to 6.9% (percentages are age-adjusted) (Table 58).

In 2014, 16.8% of adults aged 18 and over were current cigarette smokers, a decline from 2004 (20.9%). Men (18.8%) were more likely than women (14.8%) to be current cigarette smokers in 2014 (Table 47).

### Measures of Health and Disease Prevalence for the Noninstitutionalized Population

In 2012–2014, 4.9% of children under age 18 had an asthma attack in the past year, and 5.6% had a food allergy (Table 35).

Among children aged 5–17, 10.2% were diagnosed with attention deficit/hyperactivity disorder and 5.4% had serious emotional or behavioral difficulties in 2012–2014 (Table 35).

Between 2003 and 2013, the incidence rates of four selected notifiable diseases—tuberculosis, hepatitis A, hepatitis B, and meningococcal disease—decreased, while the incidence rates of Lyme disease increased 57%, to 11.62 new cases per 100,000 population in 2013, and pertussis (a vaccine-preventable disease also known as whooping cough) more than doubled to 9.12 new cases per 100,000 population in 2013. Despite the long-term decline in acute hepatitis B cases, there was a 5% increase in the number of reported cases from 2012 to 2013 (Table 33 and Figure 5).

In 2014, the percentage of adults who reported their health as fair or poor ranged from 6.1% of those aged 18–44 to 24.9% of those aged 75 and over (Table 45).

In 2013–2014, 12.0% of adults aged 45–64 and 29.4% of adults aged 65 and over had ever been told by a physician or other health professional that they had heart disease (Table 38).

In 2013–2014, 6.7% of adults aged 45–64 and 18.2% of adults aged 65 and over had ever been told by a physician or other health professional that they had cancer (excluding squamous and basal cell skin cancers) (Table 38).

In 2011–2014, one-third of adults aged 20 and over had hypertension (having measured high blood pressure or reporting taking antihypertensive medication). Of these adults aged 20 and over with hypertension, nearly one-half (47.0%) had uncontrolled high blood pressure (measured systolic pressure of at least 140 mm Hg or diastolic pressure of at least 90 mm Hg) (Table 54).

In 2014, the prevalence of self-reported serious difficulty concentrating, remembering, or making decisions was highest among men and women aged 75–84 and 85 and over and was similar among men and women in each age group. Difficulty doing errands alone increased with age, and was higher among women than men in all age groups (Figure 6).

## Utilization of Health Resources for the Noninstitutionalized Population

### Use of Health Care Services

In 2014, 14.9% of persons had no health care visits in the past 12 months, 49.8% had 1–3 health care visits, 23.3% had 4–9 visits, and 11.9% had 10 or more visits. Health care visits for illness, preventive care, or injury include visits to physician offices, emergency departments, clinics, or other locations, in addition to home visits made by health care professionals (Table 65).

In 2014, 83.0% of children aged 2–17 years, 62.0% of adults aged 18–64, and 62.4% of adults aged 65 and over had visited a dentist in the past year (Table 78).

### Use of Preventive Medical Care Services for the Noninstitutionalized Population

In 2014, 71.6% of children aged 19–35 months had completed the combined 7-vaccine series of childhood vaccinations (4 or more doses of diphtheria and tetanus toxoids and pertussis vaccine [DTP], diphtheria and tetanus toxoids vaccine [DT], or diphtheria and tetanus toxoids and acellular pertussis vaccine [DTaP]; 3 or more doses of any poliovirus vaccine; 1 or more doses of a measles-containing vaccine [MCV]; 3 or more doses or 4 or more doses of Haemophilus influenzae type b vaccine [Hib] depending on Hib vaccine product type [full series Hib]; 3 or more doses of hepatitis B vaccine; 1 or more doses of varicella vaccine; and 4 or more doses of pneumococcal conjugate vaccine [PCV]) (Table 66).

Between 2013 and 2014, receipt of the recommended three doses of human papillomavirus (HPV) vaccine for adolescents aged 13–17 increased among females from 36.8% to 39.7% and among males from 13.4% to 21.6% (Table 67).

In 2013, Pap test utilization was highest among women currently recommended for routine cervical cancer screening; 81.6% of women aged 21–44 and 73.9% of women aged 45–64 received a Pap test in the past 3 years (Table 71 and Figure 10).

In 2014, 42.2% of adults aged 18 and over had received an influenza vaccination in the past 12 months. Influenza vaccination increased with age, with 30.2% of those aged 18–44, 43.3% of those aged 45–64, and 70.1% of those aged 65 and over reporting an influenza vaccination in the past 12 months (Table 68).

In 2014, 61.3% of adults aged 65 and over had ever received a pneumococcal vaccination (Table 69).

### Difficulty Accessing Needed Medical Care, Prescription Drugs, and Dental Care Due to Cost for the Noninstitutionalized Population

In 2014, 8.2% of persons reported delaying or not receiving needed medical care due to cost, 5.6% reported not receiving needed prescription drugs due to cost, and 10.0% reported not receiving needed dental care due to cost in the past 12 months (Table 63).

Among adults aged 18–64, the percentage who reported delaying or not receiving needed medical care, not receiving needed prescription drugs, and not receiving needed dental care due to cost in the past 12 months increased 22%–31% during 2004–2010, and then declined 24%–32% during 2010–2014 (Table 63).

## Health Care Resources

In 2013, there were 27.6 physicians in patient care per 10,000 civilian population in the United States. The number of patient care physicians per 10,000 population ranged from 18.6 in Idaho to 43.0 in Massachusetts and 66.1 in the District of Columbia (Table 83).

In 2013, the United States had 4,974 community hospitals and 795,603 community hospital beds. Community hospital occupancy averaged 62.9% in 2013, down from 67.3% in 2005 (Table 89).

In 2013, there were 60.46 professionally active dentists per 100,000 civilian population in the United States. The number of dentists per 100,000 population ranged from 40.90 in Arkansas to 81.22 in New Jersey and 89.20 in the District of Columbia (Table 86).

In 2013, about 8 of every 10 office-based physicians had computerized electronic health record components that recorded patient history and demographic information, ordered prescriptions, and submitted prescriptions to the pharmacy. About 7 of 10 had components to provide electronic warnings of drug interactions and contraindications and to order lab tests electronically (Figure 13).

In 2014, there were 15,643 certified nursing homes with 1,693,943 nursing home beds. U.S. nursing home occupancy averaged 80.8% in 2014. Nursing home occupancy rates were highest in North Dakota (92.4%), Rhode Island (91.9%), South Dakota (91.9%), and the District of Columbia (91.8%) in 2014. The lowest occupancy rates were in Oregon (60.1%), Utah (64.3%), and Idaho (64.5%) (Table 92).

## Health Care Expenditures and Payers

### Health Care Expenditures

In 2014, personal health care expenditures in the United States totaled $2.6 trillion—a 5.0% increase from 2013. The per capita personal health care expenditure for the total U.S. population was $8,054 in 2014—up from $7,727 in 2013 (Table 93).

Expenditures for hospital care accounted for 37.9% of all personal health care expenditures in 2014. Physician and clinical services accounted for 23.5% of total personal health care expenditures, prescription drugs for 11.6%, and nursing care facilities and continuing care retirement communities for 6.1%; the remaining spending was for other types of personal health care expenditures (Table 94).

In 2014, prescription drug expenditures totaled $297.7 billion—up 12.2% from $265.3 billion in 2013 (Table 94).

In 2013, the average cost for the entire hospitalization involving a heart valve procedure was $51,415; a coronary artery bypass graft procedure was $41,274; cardiac pacemaker or defibrillator insertion, revision, replacement, or removal was $35,074; and spinal fusion was $28,696 (Table 96).

### Health Care Payers

In 2014, 33.9% of all personal health care expenditures were paid by private health insurance, 22.7% were paid by Medicare, and 17.4% by Medicaid; consumers paid 12.9% out-of-pocket; and the remaining expenditures were paid by other types of insurance, payers, and programs (Table 95).

In 2014, the Medicare program had 53.8 million enrollees and expenditures of $613.3 billion—up from 52.5 million enrollees and $582.9 billion in expenditures the previous year. Expenditures for the Medicare drug program (Part D) were $78.1 billion in 2014—up from $69.7 billion in 2013 (Table 107).

### Health Insurance Coverage for the Noninstitutionalized Population

The Affordable Care Act (ACA) of 2010's major provisions were in effect by January 2014. Many of these provisions are intended to expand health insurance and health benefits coverage. Between 2013 and 2014, the percentage of adults aged 18–64 who were uninsured decreased 20%, from 20.5% to 16.3% (Table 105).

From 2014 to June 2015 (preliminary data), the percentage of adults aged 18–64 who were uninsured declined 22%, to 12.7% (Martinez ME, Cohen RA. Health insurance coverage: Early release of estimates from the National Health Interview Survey, January–June 2015. NCHS; 2015. Available from: (http://www.cdc.gov/nchs/data/nhis/earlyrelease/insur201511.pdf)(Table 105).

A provision of ACA requires insurers to extend dependent coverage on a family plan until age 26, effective in 2010. This provision, along with other ACA provisions and changes in insurance coverage, has contributed to the 42% decrease in the percentage of adults aged 19–25 who were uninsured, from 33.8% in 2010 to 19.7% in 2014 (Table 105).

From 2014 to June 2015 (preliminary data), the percentage of adults aged 19–25 who were uninsured declined 19%, to 15.9% (Martinez ME, Cohen RA. Health insurance coverage: Early release of estimates from the National Health Interview Survey, January–June 2015. NCHS; 2015. Available from: (http://www.cdc.gov/nchs/data/nhis/earlyrelease/insur201511.pdf)(Table 105).

Between 2004 and 2014, the percentage of the population under age 65 with private health insurance obtained through the workplace declined from 64.0% to 56.8% (Table 103).

Between 2004 and 2014, among children in families with income of 100%–199% of the poverty level, the percentage of uninsured children under age 18 decreased from 15.1% to 8.7%, while Medicaid or Children's Health Insurance Program (CHIP) coverage among children in families with income of 100%–199% of poverty increased from 40.2% to 60.0% (Tables 104 and 105).

In 2014, Massachusetts (3.9%), Vermont (5.4%), Hawaii (5.7%), and the District of Columbia (6.1%) had the lowest percentages of persons uninsured (i.e., without public or private coverage) among those under age 65, while Alaska (19.2%), Florida (20.1%), and Texas (21.2%) had the highest percentages uninsured (Table 114).

## Special Feature on Racial and Ethnic Health Disparities

The difference between the highest (non-Hispanic black) and lowest (non-Hispanic Asian or Pacific Islander) infant mortality rates among the five racial and ethnic groups narrowed from 9.41 deaths per 1,000 live births in 1999 to 7.21 in 2013 (Figure 19).

In 2014, non-Hispanic black mothers had the highest percentage of preterm births before 37 weeks gestation (11.1%) and non-Hispanic Asian or Pacific Islander mothers had the lowest percentage (6.8%) (Figure 20).

In 2011–2014, among children and adolescents aged 2–19, Hispanic children and adolescents had the highest prevalence of obesity (21.9%) and non-Hispanic Asian children and adolescents had the lowest prevalence (8.6%) (Figure 22).

In 2011–2014 among men aged 20 and over, non-Hispanic black men had the highest prevalence of hypertension (42.4%) and Hispanic men had the lowest (27.7%); among women aged 20 and over, non-Hispanic black women had the highest prevalence of hypertension (44.0%) and non-Hispanic Asian women had the lowest (25.0%) (percentages are age-adjusted) (Figure 23).

The difference for women between the highest (non-Hispanic white) and lowest (non-Hispanic Asian) percentages of current cigarette smokers among the four racial and ethnic groups narrowed from 17.5 percentage points in 1999 to 13.2 in 2014 (percentages are age-adjusted) (Figure 24).

In 2014 among adults aged 18–64, Hispanic adults had the highest percentage of nonreceipt of dental care in the past 12 months due to cost (15.7%) and non-Hispanic Asian adults had the lowest percentage (6.3%) (Figure 27).