# Acknowledgments

Overall responsibility for planning and coordinating the content of this volume rested with the National Center for Health Statistics' (NCHS) Office of Analysis and Epidemiology, under the direction of Julia S. Holmes and Irma E. Arispe.

Production of Health, United States, 2015 was managed by Sheila J. Franco, Virginia M. Freid, and Julia S. Holmes. Preparation of the volume, including highlights, trend tables, appendixes, and index, was completed by Mary Ann Bush, La-Tonya D. Curl, Anne K. Driscoll, Catherine R. Duran, Sheila J. Franco, Virginia M. Freid, Nancy Han, Hashini S. Khajuria, Ji-Eun Kim, Florence Lee, Xianfen Li, Anita L. Powell, Ilene B. Rosen, and Ashley M. Woodall. Administrative and word processing assistance was provided by Lillie C. Featherstone.

Production of the Chartbook was managed by Sheila J. Franco and Virginia M. Freid. Data, analysis, and text for specific charts were provided by Mary Ann Bush, Juanita J. Chinn, La-Tonya D. Curl, Anne K. Driscoll, Catherine R. Duran, Sheila J. Franco, Virginia M. Freid, Nancy Han, Hashini S. Khajuria, Ji-Eun Kim, Florence Lee, Xianfen Li, Diane M. Makuc, Makram Talih, and Ashley M. Woodall.

Publication production was performed by CDC/OSELS/NCHS/OD/Office of Information Services, Information Design and Publishing Staff (IDPS). Project management was provided by Jen Hurlburt, Elom L. Lawson, and Barbara J. Wassell. Editorial review was provided by Jen Hurlburt and Barbara J. Wassell. Graphic design was provided by Odell D. Eldridge (contractor) and Kyung M. Park. Layout and production were done by Jacqueline M. Davis and Zung T. Le. Overview for IDPS publications and electronic products was provided by Kimberly N. Ross and Tommy C. Seibert, Jr. Printing was managed by Nathanael Brown, CDC/OD/OADC.

Electronic access through the NCHS website was provided by Christine J. Brown, La-Tonya D. Curl, Jacqueline M. Davis, Virginia M. Freid, Jen Hurlburt, Elom L. Lawson, Zung T. Le, Florence Lee, Anthony Lipphardt, Anita L. Powell, Anthony R. Quintana, Ilene B. Rosen, Barbara J. Wassell, and Ashley M. Woodall.

Data and technical assistance were provided by staff of the following NCHS organizations: Division of Health Care Statistics: Esther S. Hing, Eric Jamoom, Susan M. Schappert, and Victor V. Shigaev; Division of Health and Nutrition Examination Surveys: Margaret D. Carroll, Mark S. Eberhardt, Eleanor B. Fleming, Cheryl Fryar, Qiuping Gu, Brian K. Kit, Cynthia L. Ogden, and Ryne Paulose-Ram; Division of Health Interview Statistics: Patricia F. Adams, Veronica Benson, Lindsey Black, Debra Blackwell, Barbara Bloom, Tainya Clarke, Robin A. Cohen, Jacqueline Lucas, Michael Martinez, Colleen Nugent, Jeannine Schiller, Charlotte Schoenborn, Jessica Simpson, Maria Villarroel, Brian Ward, and Emily Zammitti; Division of Vital Statistics: Robert N. Anderson, Joyce A. Arbertha, Elizabeth Arias, Amy M. Branum, Sharon E. Kirmeyer, Kenneth D. Kochanek, Annie Liu, Joyce A. Martin, T.J. Mathews, Arialdi M. Miniño, Jaleh Mousavi, Sherry L. Murphy, Steven J. Steimel, Betzaida Tejada-Vera, and Elizabeth C. Wilson; Office of Analysis and Epidemiology: Li-Hui Chen, Catherine R. Duran, Deborah D. Ingram, Mitchell Loeb, Laura A. Pratt, and Cheryl V. Rose; Office of the Center Director: Juan Albertorio and Francis C. Notzon; and Office of Research and Methodology: Meena Khare.

Additional data and technical assistance were provided by the following organizations of the Centers for Disease Control and Prevention (CDC): National Center for Chronic Disease Prevention and Health Promotion: Karen Pazol; National Center for HIV/AIDS, Viral Hepatitis, STD, and TB Prevention: Lori Elmore, Anna Satcher Johnson, Laura Kann, Steve Kinchen, Jennifer A. Ludovic, and the Surveillance and Data Management Branch; Office of Public Health Scientific Services, Center for Surveillance, Epidemiology, and Laboratory Services: Ruth Ann Jajosky; by the following organizations within the Department of Health and Human Services: Agency for Healthcare Research and Quality: Kellyn V. Carper and Anne Elixhauser; Centers for Medicare & Medicaid Services: Catherine A. Curtis, Tony Dean, Maria Diacogiannis, Nathan Espinosa, Deborah W. Kidd, Barbara S. Klees, Lisa M. Mirel, Maggie S. Murgolo, Debra Reed-Gillette, Joseph F. Regan, Jeffrey S. Silverman, Christopher J. Truffer, and Lekha S. Whittle; National Institutes of Health: Nadia Howlader and Marsha Lopez; Substance Abuse and Mental Health Services Administration: Jonaki Bose, Kathy Piscopo, Neil Russell, and Albert M. Woodward; and by the following governmental and nongovernmental organizations: U.S. Census Bureau: Bernadette D. Proctor, Danielle Taylor, and Monica Wiedemann; Bureau of Labor Statistics: Elizabeth Ashack, Christen Byler, and Audrey Watson; Department of Veterans Affairs: Tom Garin and Dat Tran; American Association of Colleges of Pharmacy: Nancy T. Nguyen, Danielle A. Taylor, and Jamie N. Taylor; American Association of Colleges of Osteopathic Medicine: Linsey Jurd; American Association of Colleges of Podiatric Medicine: Moraith G. North; American Dental Education Association: Adriana R. Menezes and Bradley Munson; American Medical Association Physician Masterfile: Cheryl Ashe; Association of American Medical Colleges: Briana Gunter and Lindsay Roskovensky; Association of Schools and Colleges of Optometry: Paige Pence and Joanne Zuckerman; Association of Schools & Programs of Public Health: Emily M. Burke and Christine M. Plepys; Cowles Research Group: C. McKeen Cowles; and NOVA Research Company: Shilpa Bengeri.