# Chartbook With Special Feature on Racial and Ethnic Health Disparities

## Mortality

### Life Expectancy at Birth, by Country

In 2013, U.S. males and females ranked 25th and 27th, respectively, in life expectancy compared with males and females in other OECD countries.

Life expectancy is often used to evaluate the overall health of a population (1). Life expectancy at birth for males and females in the United States was compared with those for males and females in 30 other countries. In 2013, life expectancy at birth for males ranged from a low of 71.7 years for Mexico to a high of 80.7 years for Switzerland, with the United States (76.4 years) ranking 25th out of 31 countries. Life expectancy at birth for females ranged from a low of 77.4 years for Mexico to a high of 86.6 years for Japan, with the United States (81.2 years) tied with Poland and ranking 27th out of 31 countries.

Figure 1 Life expectancy at birth, by sex and country: Organisation for Economic Co-operation and Development (OECD) countries, 2013

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig01

NOTES: Countries with estimated life expectancies or series breaks for 2013 are not presented. Differences in life expectancy may reflect differences in reporting methods, which can vary by country, in addition to actual differences in mortality rates.

SOURCE: CDC/NCHS, Health, United States, 2015, Tables 14 and 15. Data for the United States from the National Vital Statistics System (NVSS); all other data from the Organisation for Economic Co-operation and Development (OECD).

Figure 1 consists of two bar charts, one for males and one for females, showing life expectancy at birth, by sex and Organisation for Economic Cooperation and Development country for 2013.

### Selected Causes of Death

Between 2004 and 2014, the all-cause, age-adjusted death rate decreased 12% among males and 11% among females.

During 2004–2014, age-adjusted death rates among males declined 29% for stroke, 23% for heart disease, 16% for cancer, and 10% for both diabetes and CLRD, and increased 11% for Alzheimer's disease and 4% for unintentional injuries. Among females, age-adjusted death rates declined 29% for stroke, 27% for heart disease, 21% for diabetes, and 13% for cancer, and increased 15% for Alzheimer's disease and 11% for unintentional injuries. In 2014, age-adjusted death rates among males were higher than among females for heart disease, cancer, CLRD, diabetes, stroke, and unintentional injuries and were lower among males than females for Alzheimer's disease.

Figure 2 Age-adjusted death rates for selected causes of death for all ages, by sex: United States, 2004–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig02

NOTES: CLRD is chronic lower respiratory diseases. A change in the coding rules for nephritis, nephrotic syndrome and nephrosis caused an increase in the number of deaths attributed to diabetes beginning with 2011 data. Thus, the trend for diabetes death rates should be interpreted with caution.

SOURCE: CDC/NCHS, Health, United States, 2015, Table 17. Data from the National Vital Statistics System (NVSS).

Figure 2 consists of two line graphs, one for males and one for females, showing age-adjusted death rates for selected causes of death for all ages, for 2004 through 2014.

### Suicide and Homicide

In 2014, suicide rates were higher than homicide rates for males and females of all age groups.

In 2014, suicide was the 10th and homicide the 17th leading cause of death in the U.S. (Table 19) (2). Suicide and homicide deaths impose emotional and financial costs on both families and society, and death rates for these causes differ by age and other factors (3–7). Suicide rates were higher among males than among females overall (21.1 deaths per 100,000 population compared with 6.0) (Table 30) and within each age group. Among males in 2014, suicide rates were higher among those aged 45–64 and 65 and over than among younger age groups. Among females, suicide rates were highest among those aged 45–64.

Homicide rates were higher among males than among females overall (8.0 deaths per 100,000 population compared with 2.0) (Table 29) and within each age group. Among both males and females, homicide rates were higher among those aged 15–24 and 25–44 than among older age groups in 2014.

Figure 3 Suicide and homicide death rates among persons aged 15 and over, by age and sex: United States, 2014

Excel and Powerpoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig03

SOURCE: CDC/NCHS, Health, United States, 2015, Tables 29 and 30. Data from the National Vital Statistics System (NVSS).

Figure 3 consists of two bar charts, one for suicide and one for homicide, showing death rates among persons aged 15 and over, by age and sex, for 2014.

## Natality

### Teenage Childbearing

Between 2004 and 2014, teenage birth rates declined among all racial and ethnic groups.

Teen childrearing often limits the mother's educational and occupational opportunities, and female babies born to teen mothers are more likely to become teen mothers themselves (8,9). In 2014, teen childbearing fell to a historic low of 24.2 per 1,000 females overall and for each race and Hispanic-origin group (8). Between 2004 and 2014, birth rates declined 50% for teenagers aged 15–17 and 36% for those aged 18–19 (Table 3). Among teenagers aged 15–17, birth rates decreased 44% for non-Hispanic white, 51% for American Indian or Alaska Native, 54% for non-Hispanic black, 59% for Hispanic, and 61% for Asian or Pacific Islander females. Among teenagers aged 18–19, birth rates decreased 32% for non-Hispanic white, 39% for American Indian or Alaska Native, 39% for non-Hispanic black, 47% for Hispanic, and 48% for Asian or Pacific Islander females.

Figure 4 Teenage childbearing, by maternal age and race and Hispanic origin: United States, 2004–2014

Excel and Powerpoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig04

SOURCE: CDC/NCHS, Health, United States, 2015, Table 3. Data from the National Vital Statistics System (NVSS).

Figure 4 consists of two line graphs showing teenage childbearing rates, one for maternal age 15 through 17 and one for maternal age 18 through 19, by race and Hispanic origin, for 2004 through 2014.

## Morbidity

### Notifiable Disease Rates

Between 2003 and 2013, the rates for pertussis—a vaccine-preventable disease—and Lyme disease increased, while rates for tuberculosis, hepatitis A, hepatitis B, and meningococcal disease decreased.

Public health officials rely on regular, frequent, timely reporting of notifiable diseases to identify at-risk groups, monitor trends, and control the spread of infectious diseases (10,11). Between 2003 and 2013, the incidence rates of four selected diseases decreased—hepatitis A (79% decrease), meningococcal disease (70%), hepatitis B (63%), and tuberculosis (41%)— while the rates of Lyme disease (57%) and pertussis (whooping cough) (126%) increased. The hepatitis B rate declined in the past decade, but reported cases increased 5% from 2012 to 2013.

Figure 5 Selected notifiable disease rates: United States, 2003 and 2013

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig05

NOTES: Diseases with consistent definitions and the greatest changes between 2003 and 2013 were selected for display. Food-borne illnesses were not selected due to year-to-year variation. Rates used the postcensal total resident population and may differ from those elsewhere if different population estimates were used to calculate rates.

SOURCE: CDC/NCHS, Health, United States, 2015, Table 33. Data from the National Notifiable Diseases Surveillance System (NNDSS).

Figure 5 is a bar chart showing rates for selected notifiable diseases for 2003 and 2013.

## Functional Limitations

### Disability

In 2014, disabilities related to cognition and independent living were highest in older age groups; more women than men in each age group reported difficulty doing errands alone.

In 2014, among noninstitutionalized men and women, the prevalence of self-reported serious difficulty concentrating, remembering, or making decisions was higher among older age groups (75–84 and 85 and older) than among younger age groups (18–64 and 65–74) and was similar among men and women in each age group. Difficulty doing errands alone—another disability measure—increased with age. Women in all age groups were more likely than men to report difficulty doing errands alone, ranging from 26% more likely among women aged 18–64 to 72% more likely among women aged 85 and over, compared with men in the same age groups.

Figure 6 Selected disability indicators among adults aged 18 and over, by sex and age: United States, 2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig06

NOTE: See data table for Figure 6.

SOURCE: CDC/NCHS, National Health Interview Survey (NHIS).

Figure 6 consists of two bar charts showing two selected disability measures (one measure is for serious difficulty concentrating, remembering, or making decisions and the other is for difficulty doing errands alone), among adults aged 18 and over, by sex and age, for 2014.

## Health Risk Factors

### Current Cigarette Smoking

During 2004–2014, cigarette smoking prevalence declined among women aged 18–44 and adults aged 45–64.

Smoking is associated with an increased risk of heart disease, stroke, lung and other types of cancers, and chronic lung diseases (12). During 2004–2014, the percentage of adults who smoked cigarettes declined for women aged 18–44 and for both men and women aged 45–64, and remained stable for men and women aged 65 and over. For men aged 18–44, smoking prevalence was stable from 2004–2009 and then declined through 2014. The prevalence of smoking generally was higher for men aged 18–44 and 45–64 than for women in the same age groups (except for 2012). Among adults aged 65 and over, the prevalence for men and women was similar for most years; from 2011–2014, prevalence was higher among men than women. In 2014, 18.8% of men and 14.8% of women aged 18 and over were current cigarette smokers (Table 47).

Figure 7 Current cigarette smoking among adults aged 18 and over, by sex and age: United States, 2004–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig07

SOURCE: CDC/NCHS, Health, United States, 2015, Table 47. Data from the National Health Interview Survey (NHIS).

Figure 7 consists of two line graphs, one for men and one for women, showing current cigarette smoking among adults aged 18 and over, by age groups, for 2004 through 2014.

### Children and Adolescents With Obesity

Between 1999–2002 and 2011–2014, the prevalence of obesity was stable among children aged 6–11; increased among adolescents aged 12–19; and increased from 1999–2002 to 2003–2006 among those aged 2–5, then declined through 2011–2014.

Excess body weight in children is associated with excess morbidity during childhood and excess body weight in adulthood (13–16). Obesity among children is defined as a body mass index at or above the sex-and age-specific 95th percentile of the CDC growth charts (15,16). From 1988–1994 to 1999–2002, obesity increased among children aged 2–19. Among children aged 2–5, the prevalence of obesity increased from 1999–2002 to 2003–2006 and then declined through 2011–2014. Among children aged 6–11, the prevalence of obesity was stable from 1999–2002 to 2011–2014. Between 1999–2002 and 2011–2014, the prevalence of obesity among adolescents aged 12–19 increased 28%.

Figure 8 Obesity among children and adolescents aged 2–19 years, by age: United States, 1999–2002 through 2011–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig08

SOURCE: CDC/NCHS, Health, United States, 2015, Table 59. Data from the National Health and Nutrition Examination Survey (NHANES).

Figure 8 is a line graph showing children and adolescents aged 2 through 19 years with obesity by age for four time periods: 1999 through 2002, 2003 through 2006, 2007 through 2010, and 2011 through 2014.

### Adults With Overweight and Obesity

Between 1999–2002 and 2011–2014, the prevalence of obesity among men (Grades 1, 2, and 3) and women (Grade 3 only) increased, while the prevalence of overweight but not obese declined among men and remained stable among women aged 20 and over.

Reducing the prevalence of obesity is a public health priority because obesity is correlated with excess morbidity and mortality (17–19). In particular, Grade 2 or higher obesity significantly increases the risk of death (20). Between 1999–2002 and 2011–2014, the percentage of adults aged 20 and over with Grades 1, 2, and 3 obesity increased among men. For women, the percentage of Grade 1 obesity and Grade 2 obesity remained stable while Grade 3 obesity increased. Meanwhile, the percentage of men aged 20 and over who were overweight but not obese declined and was stable among women. In 2011–2014, women were almost twice as likely to have Grade 3 obesity as men (8.9% compared with 4.9%).

Figure 9 Overweight and obesity among adults aged 20 and over, by sex and grade of obesity: United States, 1999–2002 through 2011–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig09

NOTES: BMI is body mass index. Overweight but not obese (25 ≤ BMI < 30), Grade 1 obesity (30 ≤ BMI < 35), Grade 2 obesity (35 ≤ BMI < 40), and Grade 3 obesity (BMI ≥ 40).

SOURCE: CDC/NCHS, Health, United States, 2015, Table 58. Data from the National Health and Nutrition Examination Survey (NHANES).

Figure 9 consists of two area graphs, one for men and one for women, showing the percentage of adults who were overweight but not obese and the percentages with Grade 1, Grade 2, and Grade 3 obesity, among adults aged 20 and over for four time periods: 1999 through 2002, 2003 through 2006, 2007 through 2010, and 2011 through 2014.

## Utilization

### Pap Test Use

From 2003 to 2013, Pap test utilization decreased for all age groups; the largest decreases were for women aged 18–20 and 65 and over (age groups no longer recommended for routine testing).

Pap tests have reduced cervical cancer deaths by detecting cases at earlier and more treatable stages (21). Current Pap test recommendations suggest limiting routine testing to women aged 21–65 and vary based on individual risk factors including cervical cancer risk, human papillomavirus (HPV) testing, and screening history (22). From 2003 to 2013, recent Pap testing declined for all age groups. The refined recommendations may help explain the decrease for women aged 21–44 (5%) and 45–64 (9%). The greatest decreases were for age groups for which routine testing is no longer recommended: 18–20 (39%), 65–74 (22%), and 75 and over (45%).

Figure 10 Pap test utilization within the past 3 years, by age: United States, 2003–2013

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig10

NOTES: Pap tests (Pap smears) may be used for screening or diagnostic purposes; the purpose cannot be determined from NHIS. See Appendix II, Pap smear. The 65–74 group includes women aged 65 who are still recommended to have routine testing.

SOURCE: CDC/NCHS, Health, United States, 2015, Table 71. Data from the National Health Interview Survey (NHIS).

Figure 10 is a line graph showing the percentage of women who had a Pap smear within the past 3 years, by age, for 2003, 2005, 2008, 2010, and 2013.

### Emergency Department Use

During 2004–2014, adults aged 18–64 with Medicaid coverage were more likely to have visited an emergency department within the past year than those with private coverage or the uninsured.

Emergency departments (EDs) are critical in the U.S. health care system, providing emergency and after hours care (23–25). During 2004–2014, adults aged 18–64 with Medicaid coverage were about twice as likely as those with private coverage or the uninsured to have had an ED visit in the past year. During 2004–2014, the percentage with a recent ED visit was stable for adults with Medicaid; for those with private coverage, the percentage was stable through 2010, then declined through 2014; and for the uninsured, the percentage increased during 2004–2011, then declined through 2014. Although adults with Medicaid were more likely to have an ED visit, only 23.4% of all 2014 ED visits were by those with Medicaid; 15.1% were by the uninsured, and 53.6% were by those with private coverage, reflecting the larger percentage of adults with private coverage.

Figure 11 Emergency department utilization within the past 12 months among adults aged 18–64, by type of coverage: United States, 2004–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig11

NOTE: See data table for Figure 11.

SOURCE: CDC/NCHS, Health, United States, 2015, Table 74. Data from the National Health Interview Survey (NHIS).

Figure 11 consists of a line graph and a pie chart. The line graph shows emergency department utilization within the past 12 months among adults aged 18 through 64, by type of health insurance coverage for 2004 through 2014. The pie chart shows the distribution of emergency department visits in 2014 by type of health insurance coverage for adults aged 18 through 64.

### Difficulty Accessing Needed Medical Care or Prescription Drugs Due to Cost

Uninsured adults aged 18–64 are more likely than those with Medicaid or private coverage to report difficulties affording needed medical care and prescription drugs.

Uninsured adults are more likely than the insured to delay or forego needed medical care and prescription drugs due to cost (26,27). During 2004–2014, uninsured adults were 4–5 times more likely than those with private coverage and 1½−3 times more likely than those with Medicaid to report medical care and prescription access problems. For adults with Medicaid, medical care access problems were stable until 2008 and then decreased through 2014. For those with private insurance, medical care access problems increased until 2009 and then declined through 2014. For the uninsured, medical care and prescription access problems increased (until 2010 and 2009, respectively) and then were stable for medical care and decreased through 2014 for access to drugs. Drug access problems were stable in 2004–2014 for those with private insurance but decreased for adults with Medicaid.

Figure 12 Delay or nonreceipt of needed medical care and nonreceipt of needed prescription drugs in the past 12 months due to cost among adults aged 18–64, by health insurance coverage: United States, 2004–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig12

SOURCE: CDC/NCHS, Health, United States, 2015, Table 63. Data from the National Health Interview Survey (NHIS).

Figure 12 consists of two line graphs for adults aged 18 through 64, one showing delay or nonreceipt of needed medical care due to cost in the past 12 months and one showing nonreceipt of needed prescription drugs due to cost in the past 12 months, by type of health insurance coverage, for 2004 through 2014.

## Health Care Resources

### Electronic Health Record Systems

In 2013, most physician offices had electronic health record (EHR) systems that record patient history and demographic information (83.0%), order prescriptions (82.6%), send prescriptions to the pharmacy (78.7%), warn of drug interactions and contraindications (73.8%), and order lab tests (68.9%).

EHR systems are thought to make health care delivery more efficient by improving clinician decision-making, care coordination, health care safety, and patient outcomes (28–30). In 2013, about 8 of every 10 office-based physicians had computerized components that recorded patient history and demographic information, ordered prescriptions, and sent prescriptions to the pharmacy. About 7 of every 10 had a component that warned of drug interactions and contraindications and ordered lab tests. From 2010 to 2013, the percent increase in the use of these EHR components ranged from 12% for components to record patient history and demographic information to 80% for components to send prescriptions to the pharmacy.

Figure 13 Electronic health record system components in physician offices, by selected component type: United States, 2010 and 2013

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig13

NOTE: See data table for Figure 13.

SOURCE: CDC/NCHS, National Ambulatory Medical Care Survey (NAMCS)—National Electronic Health Records Survey.

Figure 13 is a bar chart showing the percentage of physician offices with electronic health record system components, by type of component, for 2010 and 2013.

### Physicians Accepting New Patients

In 2013, physicians in urban large fringe areas (suburbs) were less likely to accept new Medicaid patients than physicians in any other urban–rural category.

Under the ACA, more Americans have health care coverage. In some areas, finding a physician who is accepting new patients may be difficult (31–33). Physician acceptance of new patients was examined by urban–rural status, which classifies physicians by the location of their practice (34). In 2013, Medicaid acceptance rates varied across urban–rural categories, with the lowest acceptance rates for physicians in urban large fringe counties (suburbs). Physicians in rural areas (micropolitan and noncore) were more likely to accept new Medicaid patients than those in urban areas. Comparing physicians' acceptance of new private to new Medicaid patients, physicians in urban areas were less likely to accept new Medicaid than new private patients, while acceptance rates for new Medicaid and private patients were similar for physicians in rural areas.

Figure 14 Office-based physicians accepting new patients, by patient source of payment and urban–rural status: United States, 2013

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig14

NOTE: See data table for Figure 14.

SOURCE: CDC/NCHS, National Ambulatory Medical Care Survey (NAMCS)—National Electronic Health Records Survey.

Figure 14 is a bar chart showing office-based physicians accepting new patients, by patient source of payment and urban-rural status, for 2013.

## Personal Health Care Expenditures

### Major Source of Funds

Between 2004 and 2014, Medicare expenditures for personal health care grew more rapidly than out-of-pocket, private insurance spending, and total Medicaid.

Between 2004 and 2014, total personal health care expenditures grew from $1.6 trillion to $2.6 trillion (Table 95). During 2004–2014, the average annual growth in expenditures was 6.8% for Medicare, 5.4% for Medicaid (federal), 4.6% for Medicaid (state), 5.1% for Medicaid (total), 4.4% for private health insurance, and 2.9% for out-of-pocket spending. In 2014, private health insurance accounted for the highest spending on personal health care at $868.8 billion, followed by Medicare at $580.7 billion. Out-of-pocket spending by individuals reached $329.8 billion in 2014, and spending on Medicaid reached $273.6 billion in federal dollars and $171.3 billion in state dollars for a total of $444.9 billion in Medicaid spending. The remainder was paid for by other types of insurance, payers, and programs (Table 95) (35).

Figure 15 Personal health care expenditures, by source of funds: United States, 2004–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig15

NOTES: Personal health care expenditures are outlays relating directly to patient care. See Appendix II, Health expenditures, national.

SOURCE: CDC/NCHS, Health, United States, 2015, Table 95. Data from the Centers for Medicare & Medicaid Services, National Health Expenditure Accounts (NHEA).

Figure 15 is a line graph showing personal health care expenditures, by source of funds, for 2004 through 2014.

## Health Insurance

### Coverage Among Adults Aged 18–64

From 2004 to June 2015, the percentage of adults aged 18–64 with Medicaid coverage increased, the percentage with private coverage decreased through 2012 and then increased through June 2015, and the percentage uninsured increased through 2013 and then declined through June 2015.

Health insurance is a major determinant of access to health care (26). Among adults aged 18–64, the percentage with private coverage declined from 2004 (71.1%) to 2012 (65.1%) and then increased through June 2015 (70.6%) (Table 102) (36). As of June 2015, 8.9 million adults aged 18–64 were covered by private plans obtained through the Health Insurance Marketplace or state-based exchanges (36). The percentage with Medicaid coverage increased from 2004 (6.8%) to June 2015 (12.2%) (Table 104) (37). The percentage of adults aged 18–64 who were uninsured increased from 2004 (19.3%) to 2013 (20.5%) and then declined through June 2015 (12.7%) (Table 105) (36).

Figure 16 Health insurance coverage among adults aged 18–64, by type of coverage: United States, 2004–June 2015 (preliminary data)

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig16

NOTE: Preliminary estimates for the first 6 months of 2015 are shown with a dashed line (36).

SOURCE: CDC/NCHS, Health, United States, 2015, Tables 102, 104, 105. Data from the National Health Interview Survey (NHIS).

Figure 16 is a line graph showing trends in health insurance coverage among adults aged 18 through 64, by type of health insurance coverage, for 2004 through June 2015. Data for 2015 are preliminary.

### Coverage by Medicaid Expansion State

Between 2013 and 2014, the percentage of adults aged 18–64 who were uninsured declined in both Medicaid expansion states (by 28%) and nonexpansion states (by 14%), and the percentage covered by Medicaid increased by 25% in Medicaid expansion states.

Under the ACA (38), states are authorized to expand Medicaid coverage to adults with low incomes, up to and including 138% of the poverty level (39). Between 2013 and 2014, the percentage of adults aged 18–64 who were uninsured declined in both Medicaid expansion states and nonexpansion states; however, the decline in the uninsured percentage was greater for states that expanded their Medicaid programs (28% compared with 14%). The percentage covered by private insurance increased by about 4% in both Medicaid expansion and nonexpansion states. Medicaid coverage increased 25% in states that expanded their programs and was stable in states that did not expand their programs.

Figure 17 Health insurance coverage among adults aged 18–64, by state Medicaid expansion status: United States, 2013 and 2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig17

NOTES: States were classified based on their decision to expand Medicaid as of January 1, 2014 (40). See data table for Figure 17.

SOURCE: CDC/NCHS, National Health Interview Survey (NHIS).

Figure 17 consists of two bar charts showing the percentage of adults aged 18 through 64 by type of health insurance coverage in states that expanded Medicaid eligibility compared with states that did not expand Medicaid eligibility, for 2013 and 2014.

## Special Feature on Racial and Ethnic Health Disparities: 30 Years After the Heckler Report

### Introduction

The 1985 Report of the Secretary's Task Force on Black and Minority Health, released by then Secretary of Health and Human Services Margaret Heckler, documented significant disparities in the burden of illness and mortality experienced by blacks and other minority groups in the U.S. population compared with whites (41). The report laid out an ambitious agenda, including improving minority access to high-quality health care, expanding health promotion and health education outreach activities, increasing the number of minority health care providers, and enhancing federal and state data collection activities to better report on minority health issues. In the 30 years since the Heckler Report, national efforts to improve minority health through outreach, programming, and monitoring have included the formation of the Department of Health and Human Services (HHS) Office of Minority Health in 1986 (42); the annual National Healthcare Quality and Disparities Reports first issued in 2003 (43); the adoption of disparities elimination as an overarching goal of Healthy People 2010 (44); and most recently, an HHS Action Plan to Reduce Racial and Ethnic Health Disparities—a comprehensive federal commitment to reduce and eventually eliminate disparities in health and health care (45).

Race is a social construct influenced by a complex set of factors (46,47). Because of the complexity and difficulty in conceptualizing and defining race, as well as the increasing representation of racial and ethnic subgroups in the United States, racial classification and data collection systems continue to evolve and expand. In 1977, the Office of Management and Budget (OMB) required that all federal data collection efforts collect data on a minimum of four race groups (American Indian or Alaskan Native, black, Asian or Pacific Islander, and white) and did not allow the reporting of more than one race (48). In 1997, in response to growing interest in more detailed reporting on race and ethnicity, OMB mandated data collection for a minimum of five race groups, splitting Asian or Pacific Islander into two categories (Asian, and Native Hawaiian or Other Pacific Islander) (49). In addition, the 1997 standards allowed respondents to report more than one race. A minimum of two categories for data collection on ethnicity, “Hispanic or Latino” and “Not Hispanic or Latino,” were also required under the 1997 OMB standards. Consequently, whereas the Heckler Report primarily documented black–white differences in health and mortality due to data limitations, this Special Feature is able to report on more detailed racial and ethnic groups. For example, Figures 19–21 display trends in infant mortality and low-risk cesarean section deliveries, and the current data on preterm births for five Hispanic-origin groups.

At the time of the Heckler Report, 22.3% of the population were considered racial or ethnic minorities (Table 1). Current Census (2014) estimates identify 37.9% of the population as racial or ethnic minorities (50). In 2014, Hispanic persons, who may be of any race, comprised 17.4% of the U.S. population. Non-Hispanic multiple race persons were 2.0% of the population. For the single race groups, non-Hispanic American Indian or Alaska Native persons were 0.7%, non-Hispanic Asian persons were 5.3%, non-Hispanic black persons were 12.4%, non-Hispanic Native Hawaiian or Other Pacific Islander persons were 0.2%, and non-Hispanic white persons were 62.1% of the U.S. population in 2014 (50).

Understanding the demographic and socioeconomic composition of U.S. racial and ethnic groups is important because these characteristics are associated with health risk factors, disease prevalence, and access to care, which in turn drive health care utilization and expenditures. Non-Hispanic white persons are, on average, older than those in other racial and ethnic groups, with a median age of 43.1 years, and Hispanic individuals are the youngest, with a median age of 28.5 years in 2014 (50). About one-quarter of black only persons (26.2%) and Hispanic persons (23.6%) lived in poverty compared with 10.1% of non-Hispanic white only persons and 12.0% of Asian only persons in 2014 (51). Non-Hispanic black only children and Hispanic children were particularly likely to live in poverty (37.3% and 31.9%, respectively, in 2014) (52). However, Hispanic individuals are often found to have quite favorable health and mortality patterns in comparison with non-Hispanic white persons and particularly with non-Hispanic black persons, despite having a disadvantaged socioeconomic profile—a pattern termed the epidemiologic paradox (53).

HHS defines a racial or ethnic health disparity as “a particular type of health difference that is closely linked with social, economic, and/or environmental disadvantage. Health disparities adversely affect groups of people who have systematically experienced greater obstacles to health based on their racial or ethnic group” (54). There are many different ways to measure racial and ethnic differences in health and mortality, which can lead to different conclusions (55–58). This Special Feature on Racial and Ethnic Health Disparities (Special Feature) uses the maximal rate difference, one of three overall measures used in Healthy People 2020 to measure differences among groups of people (see Technical Notes). The maximal rate difference is an overall measure of health disparities calculated as the absolute difference between the highest and lowest group rates in the population for a given characteristic (59). The identification of groups that experience the highest and lowest rates in this Special Feature was based on observed rates and was not tested for a statistically significant difference against other rates. Ties in highest or lowest rates were resolved by examining decimal places. With respect to changes in health disparities over time, tracking the maximal rate difference over time enables one to determine whether the absolute difference between the highest and lowest group rates is increasing, decreasing, or stable.

The Special Feature charts that follow provide detailed comparisons of key measures of mortality, natality, health conditions, health behaviors, and health care access and utilization, by race, race and ethnicity, or by detailed Hispanic origin, depending on data availability. A majority of the 10 graphs in this year's Special Feature present trends in health from 1999–2014. Results indicate that trends in health were generally positive for the overall population and several graphs illustrate success in narrowing gaps in health by racial and ethnic group. Differences in life expectancy, infant mortality, cigarette smoking among women, influenza vaccinations among those aged 65 and over, and health insurance coverage narrowed among the racial and ethnic groups. For example, the absolute difference in infant mortality rates between infants born to non-Hispanic black mothers (highest rate) and infants born to non-Hispanic Asian or Pacific Islander mothers (lowest rate) narrowed between 1999–2014. Differences by racial and ethnic group in the prevalence of high blood pressure and smoking among adult men remained stable throughout the study period, with non-Hispanic black adults more likely to have high blood pressure than adults in other racial and ethnic groups throughout the period, and non-Hispanic black and non-Hispanic white males more likely to be current smokers than Hispanic and non-Hispanic Asian men. For low-risk cesarean sections, influenza vaccinations among adults aged 18–64, and unmet dental care needs, the gap widened among the racial and ethnic groups between 1999–2014.

Despite improvements over time in many of the health measures presented in this Special Feature, disparities by race and ethnicity were found in the most recent year for all 10 measures, indicating that although progress has been made in the 30 years since the Heckler Report, elimination of disparities in health and access to health care has yet to be achieved.

### Life Expectancy at Birth

In 2014, life expectancy was longer for Hispanic men and women than for non-Hispanic white or non-Hispanic black men and women.

Life expectancy is a measure often used to gauge the overall health of a population. Life expectancy at birth represents the average number of years that a group of infants would live if the group were to experience the age-specific death rates present in the year of birth. Differences in life expectancy among various demographic subpopulations, including racial and ethnic groups, may reflect subpopulation differences in a range of factors such as socioeconomic status, access to medical care, and the prevalence of specific risk factors in a particular subpopulation (60,61).

During 1980–2014, life expectancy at birth in the United States increased from 70.0 to 76.4 years for males and from 77.4 to 81.2 years for females (Table 15, and data table for Figure 18). During this period, life expectancy at birth for males and females was longest for white persons and shortest for black persons. For both males and females, racial differences in life expectancy at birth narrowed, but persisted during 1980–2014. Life expectancy at birth was 6.9 years longer for white males than for black males in 1980, and this difference narrowed to 4.2 years in 2014. In 1980, life expectancy at birth was 5.6 years longer for white females than for black females, and this difference narrowed to 3.0 years in 2014.

In 2014, Hispanic males and females had the longest life expectancy at birth, and non-Hispanic black males and females had the shortest. In 2014, life expectancy at birth was 7.2 years longer for Hispanic males than for non-Hispanic black males and 5.9 years longer for Hispanic females than for non-Hispanic black females.

Figure 18 Life expectancy at birth, by sex, race and Hispanic origin: United States, 1980–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig18

NOTES: Life expectancy data by Hispanic origin were available starting in 2006 and were corrected to address racial and ethnic misclassification. See Technical Notes and data table for Figure 18.

SOURCE: CDC/NCHS, National Vital Statistics System (NVSS).

Figure 18 consists of a line graph showing life expectancy at birth by sex and race for 1980 through 2014 and a bar chart showing life expectancy at birth by sex, race, and Hispanic origin for 2014.

### Infant Mortality

During 1999–2013, infant mortality rates were highest among infants born to non-Hispanic black women (11.11 infant deaths per 1,000 live births in 2013).

Infant mortality, the death of a baby before his or her first birthday, is an important indicator of the health and wellbeing of a country. It not only measures the risk of infant death but it is used as an indicator of maternal health, community health status, and availability of quality health services and medical technology (62,63).

The infant mortality rate in the United States decreased from 7.04 infant deaths per 1,000 live births in 1999 to 6.75 in 2007, and then decreased at a faster rate to 5.96 in 2013. Trends in infant mortality rates during 1999–2013 varied among the five racial and ethnic groups. During 1999–2013, infants born to non-Hispanic black mothers experienced the highest rates of infant mortality (11.11 in 2013) and infants born to non-Hispanic Asian or Pacific Islander mothers experienced the lowest rates (3.90 in 2013). The difference between the highest and lowest infant mortality rates among the five racial and ethnic groups was stable from 1999 to 2006 and then narrowed from 2006 to 2013. The difference between the highest (non-Hispanic black) and lowest (non-Hispanic Asian or Pacific Islander) infant mortality rates was 9.41 deaths per 1,000 live births in 1999, compared with 7.21 in 2013.

For infants born to Hispanic mothers, the infant mortality rate remained stable during 1999–2008 (5.71 infant deaths per 1,000 live births in 1999) and then decreased to 5.00 in 2013. During 1999–2013, the infant mortality rate for Hispanic infants varied by the mother's Hispanic-origin group. Throughout this period, infants born to Puerto Rican mothers experienced the highest mortality rates. In all years except 2009, infants born to Cuban mothers and those born to Central and South American mothers experienced the lowest mortality rates at alternate times throughout 1999–2013. The difference between the highest (Puerto Rican) and lowest (Cuban) infant mortality rates among Hispanic-origin groups narrowed from 3.71 deaths per 1,000 live births in 1999 to 2.88 in 2013. During 1999–2013, the difference in infant mortality rates was narrower for mothers in the Hispanic-origin groups than for mothers in the five racial and ethnic groups.

Figure 19 Infant mortality rates, by race and Hispanic origin and detailed Hispanic origin of mother: United States, 1999–2013

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig19

NOTES: Highest and lowest rates are based on observed rates and were not tested for statistically significant differences against other rates. Ties in highest and lowest rates were resolved by looking at additional decimal places. See Technical Notes and data table for Figure 19.

SOURCE: CDC/NCHS, National Vital Statistics System (NVSS), Linked Birth/Infant Death Data Set.

Figure 19 consists of two line graphs, one for race and Hispanic origin of mother and one for detailed Hispanic origin of mother, showing infant mortality rates, for 1999 through 2013.

### Preterm Births

In 2014, non-Hispanic black mothers had the highest percentage of preterm births of the five racial and ethnic groups, and Puerto Rican mothers had the highest percentage of preterm births of the five Hispanic-origin groups.

An infant's gestational age is an important predictor of his or her survival and subsequent health (64–70). Preterm birth prior to 37 weeks gestation affects infant mortality rates and racial and ethnic disparities in infant mortality (Figure 19) (71). The degree of prematurity matters—infants born prior to 32 weeks gestation are at greatest risk of death during infancy, with the risk of infant death decreasing as gestational age increases (72).

In 2014, 7.7% of singleton births occurred before 37 weeks of gestation; 5.7% at 34–36 weeks; 0.8% at 32–33 weeks gestation; and 1.2% before 32 weeks (data table for Figure 20). In 2014, among the five racial and ethnic groups, non-Hispanic black women had the highest percentage of singleton births before 37 weeks (11.1%) and non-Hispanic Asian or Pacific Islander women had the lowest percentage (6.8%). Non-Hispanic black women also had the highest percentage of singleton preterm births at each preterm gestational age. The difference between the highest (non-Hispanic black) and lowest (non-Hispanic Asian or Pacific Islander) percentages of singleton preterm births among the five racial and ethnic groups was 4.3 percentage points (before 37 weeks), 2.0 percentage points (34–36 weeks), 0.6 percentage points (32–33 weeks), and 1.7 percentage points (before 32 weeks).

Among Hispanic-origin groups in 2014, Puerto Rican mothers had the highest percentage of singleton births before 37 weeks (9.1%) and Cuban mothers had the lowest percentage (7.2%). The difference between the highest (Puerto Rican) and lowest (Cuban) percentages of singleton preterm births among the Hispanic-origin groups was 1.9 percentage points (before 37 weeks) and 1.3 percentage points (34–36 weeks). Central and South American mothers had the lowest percentage of singleton births before 34 weeks. For preterm births before 34 weeks, the difference between the highest (Puerto Rican) and lowest (Central and South American) percentages was 0.2 percentage points (32–33 weeks) and 0.6 percentage points (before 32 weeks).

Figure 20 Preterm births, by gestational age and race and Hispanic origin and detailed Hispanic origin of mother: United States, 2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig20

NOTES: Preterm births are based on the obstetric estimate of gestational age and are for all singleton births (73). Highest and lowest percentages are based on observed percentages and were not tested for statistically significant differences against other percentages. Ties in highest and lowest percentages were resolved by looking at additional decimal places. See Technical Notes and data table for Figure 20.

SOURCE: CDC/NCHS, National Vital Statistics Survey (NVSS).

Figure 20 consists of two bar charts, one for race and Hispanic origin of mother and one for detailed Hispanic origin of mother, showing preterm births, by gestational age, for 2014.

### Low-risk Births Delivered by Cesarean Section

During 1999–2014 non-Hispanic black mothers experienced the highest percentage of low-risk cesarean deliveries among the five racial and ethnic groups (29.9% in 2014); Cuban mothers experienced the highest percentage of low-risk cesarean deliveries among the five Hispanic-origin groups (41.4% in 2014).

Cesarean deliveries comprise approximately one-third of all births in the United States (32.2% in 2014) and can place mothers and infants at increased risk for poor health outcomes (74). Over the past decade, professional medical groups have attempted to reduce low-risk cesarean deliveries defined as cesarean deliveries among full term (37 or more completed weeks of gestation), singleton, vertex (head first) births to women giving birth for the first time (75,76).

The percentage of low-risk births that were delivered by cesarean section increased from 19.5% to 26.6% during 1999–2005, stabilized during 2005–2009, and then decreased to 26.0% in 2014 (data table for Figure 21). Throughout the period 1999–2014, non-Hispanic black mothers experienced the highest percentage of low-risk cesarean deliveries (29.9% in 2014) among the five racial and ethnic groups, while non-Hispanic American Indian or Alaska Native mothers experienced the lowest percentage (21.5% in 2014). The difference between the highest (non-Hispanic black) and lowest (non-Hispanic American Indian or Alaska Native) percentages widened from 4.8 percentage points in 1999 to 8.4 percentage points in 2014.

Among Hispanic mothers, the percentage of low-risk births that were delivered by cesarean section increased from 18.7% to 24.6% during 1999–2004, increased at a slower rate from 2004–2009, and then remained stable during 2009–2014 (data table for Figure 21). Throughout the period 1999–2014 Cuban mothers experienced the highest percentage of low-risk cesarean deliveries (41.4% in 2014), while Mexican mothers experienced the lowest percentage (24.1% in 2014). Among Hispanic-origin groups, the difference between the highest and lowest percentages of low-risk cesarean deliveries was stable during 1999–2002, widened sharply during 2002–2006, and then narrowed during 2006–2014. The difference between the highest (Cuban) and lowest (Mexican) percentages was 11.7 percentage points in 1999, 21.5 percentage points in 2006, and 17.3 percentage points in 2014.

Figure 21 Low-risk births delivered by cesarean section, by race and Hispanic origin and detailed Hispanic origin of mother: United States, 1999–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig21

NOTES: The term low-risk cesarean delivery is not meant to imply that a cesarean delivery may not be medically necessary for low-risk women (75). Highest and lowest percentages are based on observed percentages and were not tested for statistically significant differences against other percentages. Ties in highest and lowest percentages were resolved by looking at additional decimal places. See Technical Notes and data table for Figure 21.

SOURCE: CDC/NCHS, National Vital Statistics System (NVSS).

Figure 21 consists of two line graphs, one for race and Hispanic origin of mother and one for detailed Hispanic origin of mother, showing the percentage of low-risk births delivered by cesarean section, for 1999 through 2014.

### Children and Adolescents With Obesity

In 2011–2014 for children and adolescents aged 2–19 years, Hispanic children and adolescents had the highest prevalence of obesity and non-Hispanic Asian children had the lowest prevalence.

Childhood obesity is a serious public health challenge in the United States and many other industrialized nations in the world (Figure 8) (19,77,78). Excess body weight in children is associated with excess morbidity in childhood and excess body weight in adulthood (13,14). Obesity among children and adolescents is defined as a body mass index at or above the sex-and age-specific 95th percentile of the CDC growth charts (15). Between 1999–2000 and 2013–2014, the percentage of children and adolescents aged 2–19 with obesity increased from 13.9% to 17.2% (79). However, among youth aged 2–19, the prevalence of obesity did not change from 2003–2004 through 2013–2014 (79).

In 2011–2014 for children and adolescents aged 2–19, the percentage with obesity was highest for Hispanic children and adolescents and lowest for non-Hispanic Asian children and adolescents. For those aged 2–19, the difference between the highest (Hispanic) and lowest (non-Hispanic Asian) percentages was 13.3 percentage points.

For children aged 2–5, the percentage with obesity was highest for Hispanic children and lowest for non-Hispanic white children. (The estimate for non-Hispanic Asian children aged 2–5 was not stable and is not shown.) The difference between the highest (Hispanic) and lowest (non-Hispanic white) percentages was 10.4 percentage points for children aged 2–5. For children aged 6–11, the percentage with obesity was highest for Hispanic children and lowest for non-Hispanic Asian children. For children aged 6–11, the difference between the highest (Hispanic) and lowest (non-Hispanic Asian) percentages was 15.2 percentage points.

In 2011–2014 for adolescents aged 12–19, the percentage with obesity was highest for Hispanic adolescents and lowest for non-Hispanic Asian adolescents. The difference between the highest (Hispanic) and lowest (non-Hispanic Asian) percentages was 13.4 percentage points for adolescents aged 12–19 years.

Figure 22 Obesity among children and adolescents aged 2–19 years, by age and race and Hispanic origin: United States, 2011–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig22

* Relative standard error (RSE) of 20%–30%. The estimate for non-Hispanic Asian children aged 2–5 is not shown because the RSE is greater than 30%.

NOTES: Obesity is defined as a body mass index at or above the sex-and age-specific 95th percentile of the CDC growth charts. Highest and lowest percentages are based on observed percentages and were not tested for statistically significant differences against other percentages. See Technical Notes and data table for Figure 22.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey (NHANES).

Figure 22 is a bar chart showing children and adolescents aged 2 through 19 years with obesity, by age and race and Hispanic origin, for 2011 through 2014.

### Hypertension

In 2011–2014, non-Hispanic black men and women were the most likely to have hypertension compared with adults in the other racial and ethnic groups.

Hypertension is an important risk factor for cardiovascular disease, stroke, kidney failure, and other health conditions (80,81). In 2011–2014, 84.1% of adults with hypertension were aware of their status, and 76.1% were taking medication to lower their blood pressure (82). Despite improvement in increasing the awareness, treatment, and control of hypertension, diagnosis and treatment of hypertension among minority groups remains a challenge (83).

Hypertension is defined as reporting taking antihypertensive medication and/or having a measured systolic blood pressure of at least 140 mm Hg or a measured diastolic blood pressure of at least 90 mm Hg. The age-adjusted percentage of adults aged 20 and over with hypertension was stable during 1999–2014 (30.8% in 2013–2014) (data table for Figure 23). During 1999–2014, non-Hispanic black adults had the highest percentage with hypertension among the three racial and ethnic groups (42.7%, age-adjusted in 2013–2014), while with the exception of 1999–2000, adults of Mexican origin had the lowest percentage with hypertension (28.8%, age-adjusted in 2013–2014). The difference between the highest and lowest age-adjusted percentages of adults with hypertension among the three racial and ethnic groups was stable during 1999–2014; in 2013–2014, the difference between the highest (non-Hispanic black) and lowest (Mexican-origin) percentages was 13.9 percentage points.

In 2011–2014, the age-adjusted percentage of adult men and women with hypertension was similar (31.0% and 29.7%, respectively, data table for Figure 23). The difference between the highest (non-Hispanic black) and lowest (Hispanic) age-adjusted percentages of men with hypertension among the four racial and ethnic groups was 14.7 percentage points; for women, the difference between the highest (non-Hispanic black) and lowest (non-Hispanic Asian) was 19.0 percentage points in 2011–2014.

Figure 23 Hypertension among adults aged 20 and over, by sex and race and Hispanic origin: United States, 1999–2000 through 2013–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig23

NOTES: Estimates are age-adjusted. Hypertension is having measured high blood pressure (systolic pressure of at least 140 mm Hg or diastolic pressure of at least 90 mm Hg) and/or respondent report of taking antihypertensive medication. Data for Hispanic adults were available starting in 2007–2008 and for non-Hispanic Asian adults in 2011–2012. Highest and lowest percentages are based on observed percentages and were not tested for statistically significant differences against other percentages. See Technical Notes and data table for Figure 23.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey (NHANES).

Figure 23 consists of a line graph for both sexes combined showing hypertension among adults aged 20 and over, by race and Hispanic origin, for 1999 to 2000 through 2013 to 2014, and a bar chart for men and women showing hypertension among adults aged 20 and over, by race and Hispanic origin, for 2011 through 2014.

### Current Cigarette Smoking

During 1999–2014, differences in cigarette smoking between racial and ethnic groups were larger for women than for men.

Smoking causes more than 480,000 deaths each year, accounting for about one in five deaths in the United States (84). Smokers are more likely to develop heart disease, stroke, and cancer. Smoking also increases the risk for diabetes, cataracts, rheumatoid arthritis, and stillbirth (85).

During 1999–2014, the age-adjusted percentage of adults aged 18 and over who were current cigarette smokers decreased from 25.2% to 19.0% for men and from 21.6% to 15.1% for women (data table for Figure 24). Within each of the four racial and ethnic groups, men were more likely to be current cigarette smokers than women.

In 2014 for men, the age-adjusted percentage of current cigarette smokers was highest for non-Hispanic black men (22.0%) and lowest for Hispanic men (13.8%). The difference between the highest and lowest age-adjusted percentages of current cigarette smokers among the four racial and ethnic groups remained stable during 1999–2014 because levels for men in all racial and ethnic groups declined similarly during this period. The difference between the highest (non-Hispanic black) and lowest (Hispanic) percentages for men was 8.2 percentage points in 2014.

For women, non-Hispanic white women consistently had the highest age-adjusted percentage of current cigarette smokers among the four racial and ethnic groups throughout 1999–2014 (18.3% in 2014), while non-Hispanic Asian women had the lowest age-adjusted percentage (5.1% in 2014). For women, the difference between the highest (non-Hispanic white) and lowest (non-Hispanic Asian) percentages narrowed from 17.5 percentage points in 1999 to 13.2 in 2014. During 1999–2014, racial and ethnic differences in cigarette smoking prevalence were larger for women than for men.

Figure 24 Current cigarette smoking among adults aged 18 and over, by sex and race and Hispanic origin: United States, 1999–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig24

NOTES: Estimates are age-adjusted. Three-year average annual estimates for the American Indian or Alaska Native population are available in the data table for Figure 24. Estimates for non-Hispanic Asian women in 2001 and 2005 have a relative standard error of 20%–30%. Highest and lowest percentages are based on observed percentages and were not tested for statistically significant differences against other percentages. Ties in highest and lowest percentages were resolved by looking at additional decimal places. See Technical Notes and data table for Figure 24.

SOURCE: CDC/NCHS, National Health Interview Survey (NHIS).

Figure 24 consists of two line graphs, one for men and one for women, showing current cigarette smoking among adults aged 18 and over, by race and Hispanic origin, for 1999 through 2014.

### Influenza Vaccination

During 1999–2014, influenza vaccination was highest for those aged 65 and over and lowest for those aged 18–64, for all racial and ethnic groups.

Influenza is a serious illness that can lead to hospitalization and sometimes death. Influenza vaccination is especially important for people who are at risk of getting seriously ill from influenza, including those with chronic conditions, older adults, and young children.

The percentage of adults aged 18–64 who received an influenza vaccination in the past 12 months remained stable during 1999–2006 and then increased to 35.8% in 2014 (data table for Figure 25). This pattern was present for all racial and ethnic groups. Decreases in influenza vaccination coverage in 2005 were related to a vaccine shortage (86). For those aged 18–64, no racial and ethnic group was consistently the most likely to receive influenza vaccination during 1999–2014. In 2014, non-Hispanic Asian adults had the highest percentage for influenza vaccination receipt (41.3%) and Hispanic adults had the lowest percentage (27.9%). For adults aged 18–64, the difference between the highest and lowest percentages of adults receiving an influenza vaccination among the four racial and ethnic groups widened from 6.9 percentage points in 1999 (non-Hispanic white compared with Hispanic) to 13.4 in 2014 (non-Hispanic Asian compared with Hispanic).

For adults aged 65 and over, the percentage who received an influenza vaccination in the past 12 months increased from 65.7% to 70.1% during 1999–2014. During this period, trends in influenza vaccination coverage varied by racial and ethnic group, and no racial and ethnic group was consistently the most or least likely to receive influenza vaccination. In 2014, non-Hispanic Asian adults had the highest percentage for receipt of influenza vaccination (72.7%) and non-Hispanic black adults had the lowest (57.4%). For adults age 65 and over, the difference between the highest (non-Hispanic Asian) and lowest (non-Hispanic black) percentages of older adults receiving an influenza vaccination among the four racial and ethnic groups was stable during 1999–2003 and then narrowed to 15.3 percentage points in 2014.

Figure 25 Influenza vaccination among adults aged 18 and over, by age and race and Hispanic origin: United States, 1999–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig25

NOTES: Three-year average annual estimates for the American Indian or Alaska Native population are available in the data table for Figure 25. Highest and lowest percentages are based on observed percentages and were not tested for statistically significant differences against other percentages. Ties in highest and lowest percentages were resolved by looking at additional decimal places. See Technical Notes and data table for Figure 25.

SOURCE: CDC/NCHS, National Health Interview Survey (NHIS).

Figure 25 consists of two line graphs, one for adults aged 18 through 64 and one for those aged 65 and over, showing influenza vaccination, by race and Hispanic origin, for 1999 through 2014.

### Health Insurance Coverage

During 1999 through the first 6 months of 2015 among adults aged 18–64, lack of health insurance coverage was highest among Hispanic adults.

Health insurance is a major determinant of access to health care. Children are less likely to be uninsured than adults aged 18–64 because they are more likely to qualify for public coverage, primarily Medicaid and the Children's Health Insurance Program (CHIP) (see data table for Figure 26 for estimates for children) (26,87). Passage of the Affordable Care Act (ACA) in 2010 (38) authorized states to expand Medicaid eligibility (88) and to establish the health insurance marketplace in 2014.

For adults aged 18–64, the percentage without coverage increased from 17.9% to 20.5% during 1999–2013, and then decreased to 12.7% in the first 6 months of 2015 (36). During this period, the trend for lack of coverage varied by racial and ethnic group.

During 1999–June 2015, Hispanic adults aged 18–64 had the highest percentage without coverage (27.2% in the first 6 months of 2015), and non-Hispanic white adults aged 18–64 had the lowest, except in the first 6 months of 2015, when non-Hispanic Asian adults had the lowest percentage without coverage.

The difference between the highest and lowest percentages of adults aged 18–64 without health insurance among the four racial and ethnic groups narrowed from 1999–June 2015. This difference was 24.9 percentage points in 1999 (Hispanic adults compared with non-Hispanic white adults) and 19.9 percentage points in the first 6 months of 2015 (Hispanic adults compared with non-Hispanic Asian adults).

Figure 26 No health insurance coverage among adults aged 18–64, by race and Hispanic origin: United States, 1999–June 2015 (preliminary data)

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig26

NOTES: Preliminary estimates for the first 6 months of 2015 are shown with a dashed line (36). Three-year average annual estimates for the American Indian or Alaska Native population are available in the data table for Figure 26. Highest and lowest percentages are based on observed percentages and were not tested for statistically significant differences against other percentages. Ties in highest and lowest percentages were resolved by looking at additional decimal places. See Technical Notes and data table for Figure 26.

SOURCE: CDC/NCHS, National Health Interview Survey (NHIS).

Figure 26 is a line graph showing no health insurance coverage among adults aged 18 through 64, by age, race, and Hispanic origin, for 1999 through June 2015. Data for 2015 are preliminary.

### Difficulty Accessing Needed Dental Care Due to Cost

During 1999–2014 among adults aged 18–64, nonreceipt of needed dental care due to cost was lowest among non-Hispanic Asian adults.

Oral health is integral to general health and wellbeing, and forgoing needed dental health care can have serious health effects (89). In general, fewer adults have dental coverage than medical coverage, and dental coverage tends to be less comprehensive (90–92). In 2012, 44% of dental expenditures among adults aged 18–64 were paid out of pocket, a higher out-of-pocket percentage than for any other type of personal health care expenditure (93).

The percentage of adults aged 18–64 who did not receive needed dental care in the past 12 months due to cost increased from 9.3% to 17.3% during 1999–2010, and then decreased to 12.6% in 2014 (data table for Figure 27).

During 1999–2014, non-Hispanic Asian adults aged 18–64 had the lowest percentage of not receiving needed dental care due to cost (6.3% in 2014) among the four racial and ethnic groups. No racial and ethnic group consistently had the highest percentage of not receiving needed dental care due to cost during 1999–2014. The difference between the highest and lowest percentages of adults not receiving needed dental care due to cost among the four racial and ethnic groups widened during 1999–2010, and then remained stable from 2010–2014 for those aged 18–64. This difference was 5.9 percentage points in 1999 (non-Hispanic black compared with non-Hispanic Asian) and 9.4 percentage points in 2014 (Hispanic compared with non-Hispanic Asian).

Figure 27 Nonreceipt of needed dental care in the past 12 months due to cost among adults aged 18–64, by race and Hispanic origin: United States, 1999–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig27

NOTES: Three-year average annual estimates for the American Indian or Alaska Native population are available in the data table for Figure 27. Highest and lowest percentages are based on observed percentages and were not tested for statistically significant differences against other percentages. See Technical Notes and data table for Figure 27.

SOURCE: CDC/NCHS, National Health Interview Survey (NHIS).

Figure 27 is a line graph showing nonreceipt of needed dental care in the past 12 months due to cost among adults aged 18 through 64, by race and Hispanic origin, for 1999 through 2014.

## Chartbook Data Tables

All 27 chartbook figures have an accompanying data table either in this section or the Trend Table section.

Data table for Figure 6 Selected disability indicators among adults aged 18 and over, by sex and age: United States, 2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig06

Sex and age | Serious difficulty concentrating, remembering, or making decisions | | Difficulty doing errands alone
Sex and age
Sex and age | Percent | SE | Percent | SE
Male
18–64 years | 4.4 | 0.2 | 3.1 | 0.2
65–74 years | 6.1 | 0.6 | 6.4 | 0.7
75–84 years | 10.8 | 1.3 | 12.9 | 1.3
85 years and over | 18.8 | 2.9 | 26.2 | 3.3
Female
18–64 years | 4.5 | 0.2 | 3.9 | 0.2
65–74 years | 5.3 | 0.5 | 9.4 | 0.7
75–84 years | 11.2 | 1.1 | 20.7 | 1.4
85 years and over | 21.5 | 2.1 | 45.0 | 2.6

SE is standard error.

NOTES: Respondents were asked, “Because of a physical, mental, or emotional condition, do you have serious difficulty concentrating, remembering, or making decisions?” See Appendix II, Instrumental activities of daily living (IADL). Proxy reporting was 3.3% for those aged 18–64, 4.8% for those aged 65–74, 6.9% for those aged 75–84, and 14.4% for those aged 85 and over. Respondents were asked, “Because of a physical, mental, or emotional condition, do you have difficulty doing errands alone such as visiting a doctor's office or shopping?” Proxy reporting was 3.7% for those aged 18–64, 6.5% for those aged 65–74 and 75–84, and 8.8% for those aged 85 and over.

SOURCE: CDC/NCHS, National Health Interview Survey. Sample family disability questionnaire. See Appendix I, National Health Interview Survey (NHIS).

Data table for Figure 11 Distribution of emergency department visits within the past 12 months for adults aged 18–64, by type of coverage: United States, 2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig11

Insurance coverage | Percent | SE
Private | 53.6 | 1.0
Medicaid | 23.4 | 0.8
Uninsured | 15.1 | 0.7
Other | 7.9 | 0.5

SE is standard error.

NOTES: Insurance categories are based on coverage at the time of interview and are mutually exclusive. Persons who reported both Medicaid and private coverage are classified as having private coverage. Medicaid coverage includes persons covered by state-sponsored health plans or the Children's Health Insurance Program (CHIP). The other insured category includes military, other government, and Medicare coverage. Persons not covered by private insurance, Medicaid, or other plans are classified as uninsured. Persons with only Indian Health Service coverage are considered uninsured. The count of emergency department visits in 2014 was determined by using the midpoint of the response categories and then summing the count. Response category None was recoded to 0 visits. Response category 1 was recoded to 1 visit. Response category 2–3 was recoded to 2.5 visits. Response category 4–5 was recoded to 4.5 visits. Response category 6–7 was recoded to 6.5 visits. Response category 8–9 was recoded to 8.5 visits. Response category 10–12 was recoded to 11 visits. Response category 13–15 was recoded to 14 visits. Response category 16 or more was recoded to 16 visits. See Appendix II, Emergency department or emergency room visit; Health insurance coverage.

SOURCE: CDC/NCHS, National Health Interview Survey (NHIS). Family core and sample adult questionnaires. See Appendix I, National Health Interview Survey (NHIS).

Data table for Figure 13 Electronic health record system components in physician offices, by selected component type: United States, 2010 and 2013

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig13

Type of component | 2010 | | 2013
Type of component
Type of component | Percent | SE | Percent | SE
Record patient history and demographic information | 74.3 | 0.9 | 83.0 | 0.9
Order prescriptions | 57.2 | 1.0 | 82.6 | 0.9
Send prescriptions to pharmacy | 43.8 | 1.1 | 78.7 | 1.0
Issue warnings of drug interactions and contraindications | 43.6 | 1.0 | 73.8 | 1.1
Order lab tests | 48.5 | 1.1 | 68.9 | 1.1

SE is standard error.

NOTES: Missing values are included in the denominator. Estimates for 2010 are based on the combined in-person and mail survey file. Estimates for 2013 are based on the mail survey file. The Health Information Technology for Economic and Clinical Health (HITECH) Act authorizes Medicare and Medicaid incentive payments to providers for the “meaningful use” of EHR—that is, using EHR components to improve care. The selected components in Figure 13 are among those designated “meaningful use.” For more information see: Hsiao CJ, Hing E. (2014). Use and characteristics of electronic health record systems among office-based physician practices: United States, 2001–2013. .

SOURCE: CDC/NCHS, National Ambulatory Medical Care Survey—National Electronic Health Records Survey. See Appendix I, National Ambulatory Medical Care Survey (NAMCS).

Data table for Figure 14 Office-based physicians accepting new patients, by patient source of payment and urban–rural status: United States, 2013

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig14

Insurance coverage and urban–rural category | Percent | SE
Accepting new patients | 95.9 | 0.5
Urban:
Large central metropolitan | 97.1 | 0.9
Large fringe metropolitan (suburbs) | 95.9 | 1.1
Medium or small metropolitan | 94.7 | 0.8
Rural:
Micropolitan (city/town) | 93.6 | 1.6
Noncore | 97.8 | 0.8
Accepting new Medicaid patients | 69.5 | 1.2
Urban:
Large central metropolitan | 69.2 | 2.3
Large fringe metropolitan (suburbs) | 58.5 | 2.4
Medium or small metropolitan | 73.0 | 1.8
Rural:
Micropolitan (city/town) | 83.8 | 3.2
Noncore | 89.6 | 3.3
Accepting new privately insured patients | 85.2 | 0.9
Urban:
Large central metropolitan | 85.1 | 1.8
Large fringe metropolitan (suburbs) | 84.4 | 1.8
Medium or small metropolitan | 85.8 | 1.3
Rural:
Micropolitan (city/town) | 86.3 | 2.2
Noncore | 84.7 | 3.4

SE is standard error.

NOTES: The target universe consists of physicians classified as providing direct patient care in office-based practices. Radiologists, anesthesiologists, and pathologists are excluded. Physician offices were classified by the 2013 NCHS urban–rural classification scheme for counties. The medium and small metropolitan categories were combined for this analysis. For more information, see: Ingram DD, Franco SJ. (2014). 2013 NCHS urban–rural classification scheme for counties. . Estimates presented here may differ from estimates based on the same data presented elsewhere if different rules were used for including observations in the analysis.

SOURCE: CDC/NCHS, National Ambulatory Medical Care Survey—National Electronic Health Records Survey. See Appendix I, National Ambulatory Medical Care Survey (NAMCS).

Data table for Figure 17 Health insurance coverage among adults aged 18–64, by state Medicaid expansion status: United States, 2013 and 2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig17

Medicaid expansion status and insurance coverage | 2013 | | 2014
Medicaid expansion status and insurance coverage
Medicaid expansion status and insurance coverage | Percent | SE | Percent | SE
States that expanded Medicaid program
Private | 65.8 | 0.5 | 68.2 | 0.5
Medicaid | 11.9 | 0.3 | 14.9 | 0.4
Uninsured | 18.5 | 0.3 | 13.4 | 0.3
States that did not expand Medicaid program
Private | 64.3 | 0.6 | 66.6 | 0.6
Medicaid | 7.7 | 0.2 | 8.3 | 0.3
Uninsured | 22.7 | 0.5 | 19.6 | 0.4

SE is standard error.

NOTES: Insurance categories are mutually exclusive. Insurance is at the time of interview. See Appendix II, Health insurance coverage. Under provisions of the Affordable Care Act (ACA) of 2010 (P.L. 111–148, P.L. 111–152), states are authorized to expand Medicaid to a new adult population. There is no deadline for states to implement the Medicaid expansion, and they may do so at any time. States were classified based on their decision to expand Medicaid as of January 1, 2014. As of January 1, 2014, 25 states and the District of Columbia have expanded their Medicaid program (40). They were: Arizona, Arkansas, California, Colorado, Connecticut, Delaware, District of Columbia, Hawaii, Illinois, Iowa, Kentucky, Maryland, Massachusetts, Michigan, Minnesota, Nevada, New Jersey, New Mexico, New York, North Dakota, Ohio, Oregon, Rhode Island, Vermont, Washington, and West Virginia. States that had not expanded their Medicaid programs as of January 1, 2014, were: Alabama, Alaska, Florida, Georgia, Idaho, Indiana, Kansas, Louisiana, Maine, Mississippi, Missouri, Montana, Nebraska, New Hampshire, North Carolina, Oklahoma, Pennsylvania, South Carolina, South Dakota, Tennessee, Texas, Utah, Virginia, Wisconsin, and Wyoming.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Data table for Figure 18 Life Expectancy at birth, by sex, race and Hispanic origin: United States, 1980–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig18

Year | All races | | | White | | | Black or African American
Year
Year | Both sexes | Male | Female | Both sexes | Male | Female | Both sexes | Male | Female
| Life expectancy (years)
1980 | 73.7 | 70.0 | 77.4 | 74.4 | 70.7 | 78.1 | 68.1 | 63.8 | 72.5
1981 | 74.1 | 70.4 | 77.8 | 74.8 | 71.1 | 78.4 | 68.9 | 64.5 | 73.2
1982 | 74.5 | 70.8 | 78.1 | 75.1 | 71.5 | 78.7 | 69.4 | 65.1 | 73.6
1983 | 74.6 | 71.0 | 78.1 | 75.2 | 71.6 | 78.7 | 69.4 | 65.2 | 73.5
1984 | 74.7 | 71.1 | 78.2 | 75.3 | 71.8 | 78.7 | 69.5 | 65.3 | 73.6
1985 | 74.7 | 71.1 | 78.2 | 75.3 | 71.8 | 78.7 | 69.3 | 65.0 | 73.4
1986 | 74.7 | 71.2 | 78.2 | 75.4 | 71.9 | 78.8 | 69.1 | 64.8 | 73.4
1987 | 74.9 | 71.4 | 78.3 | 75.6 | 72.1 | 78.9 | 69.1 | 64.7 | 73.4
1988 | 74.9 | 71.4 | 78.3 | 75.6 | 72.2 | 78.9 | 68.9 | 64.4 | 73.2
1989 | 75.1 | 71.7 | 78.5 | 75.9 | 72.5 | 79.2 | 68.8 | 64.3 | 73.3
1990 | 75.4 | 71.8 | 78.8 | 76.1 | 72.7 | 79.4 | 69.1 | 64.5 | 73.6
1991 | 75.5 | 72.0 | 78.9 | 76.3 | 72.9 | 79.6 | 69.3 | 64.6 | 73.8
1992 | 75.8 | 72.3 | 79.1 | 76.5 | 73.2 | 79.8 | 69.6 | 65.0 | 73.9
1993 | 75.5 | 72.2 | 78.8 | 76.3 | 73.1 | 79.5 | 69.2 | 64.6 | 73.7
1994 | 75.7 | 72.4 | 79.0 | 76.5 | 73.3 | 79.6 | 69.5 | 64.9 | 73.9
1995 | 75.8 | 72.5 | 78.9 | 76.5 | 73.4 | 79.6 | 69.6 | 65.2 | 73.9
1996 | 76.1 | 73.1 | 79.1 | 76.8 | 73.9 | 79.7 | 70.2 | 66.1 | 74.2
1997 | 76.5 | 73.6 | 79.4 | 77.1 | 74.3 | 79.9 | 71.1 | 67.2 | 74.7
1998 | 76.7 | 73.8 | 79.5 | 77.3 | 74.5 | 80.0 | 71.3 | 67.6 | 74.8
1999 | 76.7 | 73.9 | 79.4 | 77.3 | 74.6 | 79.9 | 71.4 | 67.8 | 74.7
2000 | 76.8 | 74.1 | 79.3 | 77.3 | 74.7 | 79.9 | 71.8 | 68.2 | 75.1
2001 | 77.0 | 74.3 | 79.5 | 77.5 | 74.9 | 80.0 | 72.0 | 68.5 | 75.3
2002 | 77.0 | 74.4 | 79.6 | 77.5 | 74.9 | 80.1 | 72.2 | 68.7 | 75.4
2003 | 77.2 | 74.5 | 79.7 | 77.7 | 75.1 | 80.2 | 72.4 | 68.9 | 75.7
2004 | 77.6 | 75.0 | 80.1 | 78.1 | 75.5 | 80.5 | 72.9 | 69.4 | 76.1
2005 | 77.6 | 75.0 | 80.1 | 78.0 | 75.5 | 80.5 | 73.0 | 69.5 | 76.2
2006 | 77.8 | 75.2 | 80.3 | 78.3 | 75.8 | 80.7 | 73.4 | 69.9 | 76.7
2007 | 78.1 | 75.5 | 80.6 | 78.5 | 76.0 | 80.9 | 73.8 | 70.3 | 77.0
2008 | 78.2 | 75.6 | 80.6 | 78.5 | 76.1 | 80.9 | 74.3 | 70.9 | 77.3
2009 | 78.5 | 76.0 | 80.9 | 78.8 | 76.4 | 81.2 | 74.7 | 71.4 | 77.7
2010 | 78.7 | 76.2 | 81.0 | 78.9 | 76.5 | 81.3 | 75.1 | 71.8 | 78.0
2011 | 78.7 | 76.3 | 81.1 | 79.0 | 76.6 | 81.3 | 75.3 | 72.2 | 78.2
2012 | 78.8 | 76.4 | 81.2 | 79.1 | 76.7 | 81.4 | 75.5 | 72.3 | 78.4
2013 | 78.8 | 76.4 | 81.2 | 79.1 | 76.7 | 81.4 | 75.5 | 72.3 | 78.4
2014 | 78.8 | 76.4 | 81.2 | 79.0 | 76.7 | 81.4 | 75.6 | 72.5 | 78.4

Year | Hispanic 1 | | | Not Hispanic or Latino
Year | Hispanic 1
Year | Hispanic 1 | | | White | | | Black or African American
Year
Year | Both sexes | Male | Female | Both sexes | Male | Female | Both sexes | Male | Female
2014 | 81.8 | 79.2 | 84.0 | 78.8 | 76.5 | 81.1 | 75.2 | 72.0 | 78.1

1 Persons of Hispanic origin may be of any race. See Appendix II, Hispanic origin. Life expectancies for the Hispanic population are adjusted for underreporting of Hispanic ethnicity on the death certificate, but are not adjusted to account for the potential effects of return migration. To address the effects of age misstatement at the oldest ages, the probability of death for Hispanic persons ages 80 and over is estimated as a function of non-Hispanic white mortality with the use of the Brass relational logit model. See Appendix II, Race, for a discussion of sources of bias in death rates by race and Hispanic origin.

NOTES: Populations for computing life expectancy for 1991–1999 are 1990-based postcensal estimates of the U.S. resident population. Populations for computing life expectancy for 2001–2009 were based on intercensal population estimates of the U.S. resident population. Populations for computing life expectancy for 2010 were based on 2010 census counts. Life expectancy for 2011 and beyond was computed using 2010-based postcensal estimates. See Appendix I, Population Census and Population Estimates. In 1997, life table methodology was revised to construct complete life tables by single years of age that extend to age 100. ( Anderson RN. (1999). Method for constructing complete annual U.S. life tables. Vital Health Stat. .) Previously, abridged life tables were constructed for 5-year age groups ending with 85 and over. In 2000, the life table methodology was revised. The revised methodology is similar to that developed for the 1999–2001 decennial life tables. In 2008, the life table methodology was further refined. See Appendix II, Life expectancy. Starting with 2003 data, some states allowed the reporting of more than one race on the death certificate. The multiple-race data for these states were bridged to the single-race categories of the 1977 Office of Management and Budget standards, for comparability with other states. The race groups, white and black include persons of Hispanic and non-Hispanic origin. Persons of Hispanic origin may be of any race. See Appendix II, Race. Life expectancy is not currently available for persons of other racial and ethnic groups. Also see Table 15 and Figure 1.

SOURCE: CDC/NCHS, National Vital Statistics System, public-use Mortality Files; Arias E. (2010). United States life tables by Hispanic origin. Vital health statistics. . NCHS. Deaths: Final data for 2014. National vital statistics reports. . See Appendix I, National Vital Statistics System (NVSS).

Data table for Figure 19 Infant mortality rates, by race and Hispanic origin of mother: United States, 1999–2013

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig19

Year | Total 2 | Race and Hispanic origin of mother 1
Year | Total 2
Year | Total 2 | Hispanic or Latina | Not Hispanic or Latina
Year | Total 2 | Hispanic or Latina
Year | Total 2 | Hispanic or Latina | White | Black or African American | Asian or Pacific Islander | American Indian or Alaska Native
| Infant deaths per 1,000 live births^3^
1999 | 7.04 | 5.71 | 5.76 | 14.14 | 4.73 | 9.35
2000 | 6.89 | 5.59 | 5.70 | 13.59 | 4.79 | 8.19
2001 | 6.84 | 5.44 | 5.72 | 13.46 | 4.65 | 9.67
2002 | 6.95 | 5.62 | 5.80 | 13.89 | 4.66 | 8.67
2003 | 6.84 | 5.65 | 5.70 | 13.60 | 4.68 | 8.72
2004 | 6.78 | 5.55 | 5.66 | 13.60 | 4.55 | 8.62
2005 | 6.86 | 5.62 | 5.76 | 13.63 | 4.77 | 8.31
2006 | 6.68 | 5.41 | 5.58 | 13.35 | 4.40 | 8.64
2007 | 6.75 | 5.51 | 5.63 | 13.32 | 4.60 | 9.38
2008 | 6.61 | 5.59 | 5.53 | 12.67 | 4.39 | 8.66
2009 | 6.39 | 5.29 | 5.33 | 12.40 | 4.28 | 9.17
2010 | 6.14 | 5.25 | 5.18 | 11.46 | 4.17 | 8.65
2011 | 6.07 | 5.15 | 5.07 | 11.45 | 4.18 | 8.52
2012 | 5.98 | 5.11 | 5.04 | 11.19 | 3.97 | 8.74
2013 | 5.96 | 5.00 | 5.06 | 11.11 | 3.90 | 7.72

Year | Detailed Hispanic origin of mother 1
Year
Year | Mexican | Puerto Rican | Cuban | Central and South American | Other and unknown Hispanic or Latina
| Infant deaths per 1,000 live births^3^
1999 | 5.51 | 8.35 | 4.64 | 4.67 | 7.24
2000 | 5.43 | 8.20 | 4.57 | 4.64 | 6.88
2001 | 5.22 | 8.53 | 4.25 | 4.97 | 6.02
2002 | 5.42 | 8.19 | 3.74 | 5.06 | 7.15
2003 | 5.49 | 8.18 | 4.59 | 5.04 | 6.66
2004 | 5.47 | 7.82 | 4.57 | 4.65 | 6.72
2005 | 5.53 | 8.31 | 4.45 | 4.69 | 6.44
2006 | 5.34 | 8.02 | 5.06 | 4.52 | 5.78
2007 | 5.42 | 7.72 | 5.21 | 4.57 | 6.41
2008 | 5.58 | 7.29 | 4.88 | 4.76 | 5.86
2009 | 5.12 | 7.19 | 5.75 | 4.47 | 6.06
2010 | 5.12 | 7.09 | 3.81 | 4.43 | 6.09
2011 | 4.99 | 7.84 | 4.34 | 4.35 | 5.41
2012 | 5.02 | 6.86 | 4.99 | 4.14 | 5.59
2013 | 4.90 | 5.92 | 3.04 | 4.30 | 5.88

1 Persons of Hispanic origin may be of any race. Starting with 2003 data, some states reported multiple-race data. The multiple-race data for these states were bridged to the single-race categories of the 1977 Office of Management and Budget standards, for comparability with other states. See Appendix II, Hispanic origin; Race.

2 Includes all infant deaths not shown separately.

3 Infant is under age 1 year.

NOTES: Rates based on a period file using weighted data. Also see Table 10.

SOURCE: CDC/NCHS, National Vital Statistics System, public-use Linked Birth/Infant Death Data Set. See Appendix I, National Vital Statistics System (NVSS).

Data table for Figure 20 Preterm births, by gestational age and race and Hispanic origin and detailed Hispanic origin of mother: United States, 2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig20

Preterm births by gestational age, in weeks 2 | Total 3 | Race and Hispanic origin of mother 1
Preterm births by gestational age, in weeks 2 | Total 3
Preterm births by gestational age, in weeks 2 | Total 3 | Hispanic or Latina | Not Hispanic or Latina
Preterm births by gestational age, in weeks 2 | Total 3 | Hispanic or Latina
Preterm births by gestational age, in weeks 2 | Total 3 | Hispanic or Latina | White | Black or African American | Asian or Pacific Islander | American Indian or Alaska Native
| Percent of live singleton births that were preterm
Less than 37 | 7.7 | 7.7 | 6.9 | 11.1 | 6.8 | 9.0
34–36 | 5.7 | 5.7 | 5.3 | 7.2 | 5.2 | 6.8
32–33 | 0.8 | 0.8 | 0.7 | 1.3 | 0.7 | 1.0
Less than 32 | 1.2 | 1.2 | 0.9 | 2.6 | 0.9 | 1.2
| Standard error
Less than 37 | 0.01 | 0.03 | 0.02 | 0.04 | 0.05 | 0.15
34–36 | 0.01 | 0.02 | 0.02 | 0.03 | 0.04 | 0.13
32–33 | 0.00 | 0.01 | 0.01 | 0.02 | 0.02 | 0.05
Less than 32 | 0.01 | 0.01 | 0.01 | 0.02 | 0.02 | 0.06

Preterm births by gestational age, in weeks 2 | Detailed Hispanic origin of mother 1
Preterm births by gestational age, in weeks 2
Preterm births by gestational age, in weeks 2 | Mexican | Puerto Rican | Cuban | Central and South American | Other and unknown Hispanic or Latina
| Percent of live singleton births that were preterm
Less than 37 | 7.6 | 9.1 | 7.2 | 7.2 | 8.3
34–36 | 5.6 | 6.4 | 5.1 | 5.3 | 6.1
32–33 | 0.8 | 1.0 | 0.9 | 0.8 | 0.9
Less than 32 | 1.1 | 1.7 | 1.2 | 1.1 | 1.3
| Standard error
Less than 37 | 0.04 | 0.11 | 0.18 | 0.07 | 0.07
34–36 | 0.03 | 0.09 | 0.16 | 0.06 | 0.06
32–33 | 0.01 | 0.04 | 0.07 | 0.02 | 0.03
Less than 32 | 0.01 | 0.05 | 0.08 | 0.03 | 0.03

0.00 Quantity more than zero but less than 0.005.

1 Persons of Hispanic origin may be of any race. Starting with 2003 data, some states reported multiple-race data. The multiple-race data for these states were bridged to the single-race categories of the 1977 Office of Management and Budget standards, for comparability with other states. See Appendix II, Hispanic origin; Race.

2 Preterm births are based on the obstetric estimate of gestational age and are for all singleton births. For more information on the obstetric estimates, see: Martin JA, Osterman MJK, Kirmeyer SE, Gregory ECW. (2015). Measuring gestational age in vital statistics data: Transitioning to the obstetric estimate. National vital statistics reports. .

3 Includes all preterm births not shown separately.

NOTES: Ties in highest and lowest rates were resolved by looking at additional decimal places. See Technical Notes.

SOURCE: CDC/NCHS, National Vital Statistics System, public-use Birth File. See Appendix I, National Vital Statistics System (NVSS).

Data table for Figure 21 Low-risk births delivered by cesarean section, by race and Hispanic origin and detailed Hispanic origin of mother: United States, 1999–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig21

Year | Total 2 | Race and Hispanic origin of mother 1
Year | Total 2
Year | Total 2 | Hispanic or Latina | Not Hispanic or Latina
Year | Total 2 | Hispanic or Latina
Year | Total 2 | Hispanic or Latina | White | Black or African American | Asian or Pacific Islander | American Indian or Alaska Native
| Percent of low-risk births delivered by cesarean section^3^
1999 | 19.5 | 18.7 | 19.2 | 21.9 | 19.6 | 17.1
2000 | 20.3 | 19.4 | 20.1 | 23.0 | 20.0 | 18.0
2001 | 21.6 | 20.6 | 21.4 | 24.3 | 21.9 | 18.8
2002 | 23.1 | 21.9 | 22.8 | 25.9 | 23.2 | 20.4
2003 | 24.3 | 23.2 | 24.0 | 27.4 | 24.9 | 21.1
2004 | 25.7 | 24.6 | 25.4 | 28.8 | 26.6 | 22.2
2005 | 26.6 | 25.1 | 26.4 | 29.8 | 27.8 | 23.2
2006 | 27.1 | 25.3 | 27.0 | 30.1 | 27.7 | 24.5
2007 | 27.5 | 26.0 | 27.4 | 30.5 | 28.3 | 24.5
2008 | 27.8 | 26.2 | 27.5 | 30.7 | 29.1 | 23.1
2009 | 28.1 | 27.0 | 27.7 | 31.1 | 29.6 | 24.1
2010 | 27.6 | 26.7 | 27.0 | 31.0 | 29.0 | 23.8
2011 | 27.3 | 26.6 | 26.6 | 30.9 | 28.8 | 22.1
2012 | 27.3 | 26.8 | 26.5 | 31.0 | 28.5 | 23.5
2013 | 26.9 | 26.6 | 25.9 | 30.8 | 28.6 | 23.0
2014^4^ | 26.0 | 25.8 | 25.0 | 29.9 | 27.6 | 21.5
| Standard error
1999 | 0.03 | 0.08 | 0.04 | 0.10 | 0.15 | 0.37
2000 | 0.03 | 0.08 | 0.04 | 0.10 | 0.14 | 0.37
2001 | 0.04 | 0.08 | 0.05 | 0.10 | 0.15 | 0.37
2002 | 0.04 | 0.08 | 0.05 | 0.10 | 0.15 | 0.38
2003 | 0.04 | 0.08 | 0.05 | 0.11 | 0.15 | 0.38
2004 | 0.04 | 0.08 | 0.05 | 0.11 | 0.15 | 0.39
2005 | 0.04 | 0.08 | 0.05 | 0.11 | 0.15 | 0.39
2006 | 0.04 | 0.08 | 0.05 | 0.11 | 0.15 | 0.39
2007 | 0.04 | 0.08 | 0.05 | 0.11 | 0.15 | 0.39
2008 | 0.04 | 0.08 | 0.05 | 0.11 | 0.15 | 0.38
2009 | 0.04 | 0.08 | 0.05 | 0.11 | 0.15 | 0.39
2010 | 0.04 | 0.09 | 0.05 | 0.11 | 0.15 | 0.39
2011 | 0.04 | 0.09 | 0.05 | 0.11 | 0.15 | 0.39
2012 | 0.04 | 0.09 | 0.05 | 0.11 | 0.15 | 0.40
2013 | 0.04 | 0.09 | 0.05 | 0.11 | 0.15 | 0.40
2014^4^ | 0.04 | 0.09 | 0.05 | 0.11 | 0.14 | 0.40

Year | Detailed Hispanic origin of mother 1
Year
Year | Mexican | Puerto Rican | Cuban | Central and South American | Other and unknown Hispanic or Latina
| Percent of low-risk births delivered by cesarean section^3^
1999 | 18.0 | 19.2 | 29.7 | 20.4 | 18.4
2000 | 18.6 | 20.5 | 30.7 | 21.2 | 19.1
2001 | 19.8 | 21.3 | 31.5 | 22.1 | 20.7
2002 | 21.1 | 23.2 | 32.8 | 23.5 | 21.7
2003 | 22.3 | 24.3 | 36.6 | 25.0 | 22.6
2004 | 23.5 | 26.8 | 38.5 | 26.8 | 23.7
2005 | 23.5 | 27.3 | 42.1 | 27.6 | 26.4
2006 | 23.3 | 28.8 | 44.8 | 27.7 | 27.5
2007 | 24.0 | 28.8 | 45.3 | 28.6 | 28.1
2008 | 24.5 | 29.0 | 45.4 | 28.6 | 26.8
2009 | 24.9 | 29.4 | 44.2 | 30.0 | 28.2
2010 | 24.6 | 29.4 | 42.0 | 29.5 | 28.0
2011 | 24.8 | 28.9 | 42.0 | 29.1 | 26.8
2012 | 25.0 | 28.9 | 43.3 | 29.4 | 27.1
2013 | 24.7 | 28.3 | 42.3 | 29.1 | 27.2
2014^4^ | 24.1 | 27.3 | 41.4 | 27.9 | 26.0
| Standard error
1999 | 0.09 | 0.29 | 0.66 | 0.22 | 0.30
2000 | 0.09 | 0.30 | 0.65 | 0.21 | 0.31
2001 | 0.09 | 0.30 | 0.63 | 0.21 | 0.32
2002 | 0.09 | 0.31 | 0.63 | 0.21 | 0.32
2003 | 0.10 | 0.31 | 0.63 | 0.20 | 0.33
2004 | 0.10 | 0.32 | 0.64 | 0.20 | 0.34
2005 | 0.10 | 0.31 | 0.64 | 0.20 | 0.32
2006 | 0.10 | 0.31 | 0.63 | 0.20 | 0.30
2007 | 0.10 | 0.30 | 0.62 | 0.20 | 0.28
2008 | 0.10 | 0.30 | 0.62 | 0.21 | 0.23
2009 | 0.10 | 0.30 | 0.62 | 0.22 | 0.23
2010 | 0.11 | 0.31 | 0.62 | 0.22 | 0.23
2011 | 0.11 | 0.30 | 0.61 | 0.23 | 0.21
2012 | 0.11 | 0.31 | 0.62 | 0.24 | 0.21
2013 | 0.11 | 0.30 | 0.58 | 0.24 | 0.22
2014^4^ | 0.11 | 0.30 | 0.55 | 0.22 | 0.21

1 Persons of Hispanic origin may be of any race. Starting with 2003 data, some states reported multiple-race data. The multiple-race data for these states were bridged to the single-race categories of the 1977 Office of Management and Budget standards, for comparability with other states. See Appendix II, Hispanic origin; Race.

2 Includes all low-risk cesarean section births not shown separately.

3 Low-risk cesarean delivery is defined as singleton, term (37 or more weeks of gestation by last menstrual period estimate for data years 1999–2013 and the obstetric estimate for 2014), vertex (not breech) cesarean delivery to women having a first birth per 100 women delivering singleton, term, vertex, first births.

4 For 2014, the definition of term birth was based on the obstetric estimate of gestational age. For more information on the obstetric estimate, see: Martin JA, Osterman MJK, Kirmeyer SE, Gregory ECW. (2015). Measuring gestational age in vital statistics data: Transitioning to the obstetric estimate. National vital statistics reports. . Use of the obstetric estimate instead of the last menstrual period had a statistically significant but small impact on the percentage of women with low-risk cesarean section births.

NOTES: Ties in highest and lowest rates were resolved by looking at additional decimal places. See Technical Notes.

SOURCE: CDC/NCHS, National Vital Statistics System, public-use Birth File. See Appendix I, National Vital Statistics System (NVSS).

Data table for Figure 22 Obesity among children and adolescents aged 2–19, by age and race and Hispanic origin: United States, 2011–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig22

Age | Total 2 | Race and Hispanic origin 1
Age | Total 2
Age | Total 2 | Hispanic or Latino | Not Hispanic or Latino
Age | Total 2 | Hispanic or Latino
Age | Total 2 | Hispanic or Latino | White only | Black or African American only | Asian only
| Percent with obesity^3^
2–19 | 17.0 | 21.9 | 14.7 | 19.5 | 8.6
2–5 years | 8.9 | 15.6 | *5.2 | 10.4 | *
6–11 years | 17.5 | 25.0 | 13.6 | 21.4 | *9.8
12–19 years | 20.5 | 22.8 | 19.6 | 22.6 | 9.4
| Standard error
2–19 | 0.7 | 0.9 | 1.2 | 1.2 | 1.1
2–5 years | 0.9 | 1.6 | 1.2 | 1.5 | *
6–11 years | 1.2 | 1.4 | 2.0 | 2.0 | 2.0
12–19 years | 1.4 | 1.6 | 2.5 | 2.3 | 1.6

1 Persons of Hispanic origin may be of any race. Starting with 1999 data, race-specific estimates are tabulated according to the 1997 Revisions to the Standards for the Classification of Federal Data on Race and Ethnicity. The three non-Hispanic race categories shown in the table conform to the 1997 Standards. Race-specific estimates are for persons who reported only one racial group. See Appendix II, Hispanic origin; Race.

2 Includes all persons not shown separately.

3 Obesity is defined as a body mass index at or above the sex- and age-specific 95th percentile of the CDC growth charts. Pregnant women are excluded.

NOTE: Also see Table 59 and Figure 8.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey. See Appendix I, National Health and Nutrition Examination Survey (NHANES).

Data table for Figure 23 Hypertension among adults aged 20 and over, by sex and race and Hispanic origin: United States, 1999–2000 through 2013–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig23

Characteristic | 1999–2000 | 2001–2002 | 2003–2004 | 2005–2006 | 2007–2008 | 2009–2010 | 2011–2012 | 2013–2014
| Percent with hypertension^1^
Both sexes
20 years and over, crude^2^ | 28.9 | 28.9 | 32.5 | 31.7 | 32.6 | 31.9 | 32.5 | 33.5
20 years and over, age-adjusted^2,3^ | 30.0 | 29.7 | 32.1 | 30.5 | 31.2 | 30.0 | 30.0 | 30.8
Race and Hispanic origin^3,4^
Mexican origin | 29.4 | 25.2 | 29.9 | 24.4 | 28.9 | 28.2 | 28.0 | 28.8
Not Hispanic or Latino:
White only | 28.4 | 27.9 | 30.8 | 29.1 | 30.7 | 28.6 | 28.6 | 29.6
Black only | 40.9 | 43.4 | 42.6 | 44.1 | 42.4 | 42.9 | 43.9 | 42.7
| Standard error
Both sexes
20 years and over, crude^2^ | 1.5 | 1.3 | 1.3 | 1.2 | 0.9 | 1.3 | 1.5 | 1.0
20 years and over, age-adjusted^2,3^ | 1.4 | 1.0 | 1.0 | 1.2 | 0.7 | 0.8 | 0.7 | 0.8
Race and Hispanic origin^3,4^
Mexican origin | 1.5 | 1.1 | 2.0 | 1.6 | 1.4 | 1.1 | 2.5 | 1.5
Not Hispanic or Latino:
White only | 1.7 | 1.1 | 1.2 | 1.3 | 1.0 | 1.1 | 0.8 | 0.9
Black only | 1.1 | 1.9 | 1.8 | 1.7 | 1.8 | 1.6 | 1.0 | 1.5

Characteristic | 2011–2014
| Percent | Standard error
Both sexes
20 years and over, crude^2^ | 33.0 | 0.9
20 years and over, age-adjusted^2,3^ | 30.4 | 0.5
Race and Hispanic origin^3,4^
Hispanic or Latino | 28.2 | 1.1
Not Hispanic or Latino:
White only | 29.1 | 0.6
Black only | 43.3 | 0.9
Asian only | 26.5 | 1.1
Men
20 years and over, crude^2^ | 32.6 | 1.1
20 years and over, age-adjusted^2,3^ | 31.0 | 0.7
Race and Hispanic origin^3,4^
Hispanic or Latino | 27.7 | 1.5
Not Hispanic or Latino:
White only | 30.2 | 1.0
Black only | 42.4 | 1.2
Asian only | 28.0 | 2.0
Women
20 years and over, crude^2^ | 33.4 | 1.0
20 years and over, age-adjusted^2,3^ | 29.7 | 0.8
Race and Hispanic origin^3,4^
Hispanic or Latina | 28.6 | 1.1
Not Hispanic or Latina:
White only | 28.0 | 0.8
Black only | 44.0 | 1.4
Asian only | 25.0 | 1.0

1 Hypertension is having measured high blood pressure (systolic pressure of at least 140 mm Hg or diastolic pressure of at least 90 mm Hg) and/or respondent report of taking antihypertensive medication. Excludes pregnant women.

2 Includes all persons not shown separately.

3 Estimates are age-adjusted to the year 2000 standard population using five age groups: 20–34 years, 35–44 years, 45–54 years, 55–64 years, and 65 years and over. Age-adjusted estimates in this table may differ from other age-adjusted estimates based on the same data and presented elsewhere if different age groups are used in the adjustment procedure. See Appendix II, Age adjustment.

4 Persons of Mexican or Hispanic origin may be of any race. Starting with 1999 data, race-specific estimates are tabulated according to the 1997 Revisions to the Standards for the Classification of Federal Data on Race and Ethnicity and are not strictly comparable with estimates for earlier years. The three non-Hispanic race categories shown in the table conform to the 1997 Standards. Starting with 1999 data, race-specific estimates are for persons who reported only one racial group. Data for Hispanic adults became available in 2007–2008 and for Asian adults starting in 2011–2012. See Appendix II, Hispanic origin; Race.

NOTE: Also see Table 54.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey. See Appendix I, National Health and Nutrition Examination Survey (NHANES).

Data table for Figure 24 Current cigarette smoking among adults aged 18 and over, by sex and race and Hispanic origin: United States, 1999–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig24

Sex, age, and year | Total 2 | | Race and Hispanic origin 1
Sex, age, and year | Total 2
Sex, age, and year | Total 2 | | Hispanic or Latino 3 | Not Hispanic or Latino 3
Sex, age, and year | | | Hispanic or Latino 3
Sex, age, and year | Crude | Age-adjusted 3 | Hispanic or Latino 3 | White only | Black only | Asian only
Men, 18 years and over | Percent current smokers^4^
1999 | 25.7 | 25.2 | 22.7 | 25.4 | 28.4 | 23.5
2000 | 25.6 | 25.2 | 23.5 | 25.8 | 25.7 | 19.5
2001 | 25.1 | 24.6 | 20.7 | 25.4 | 27.7 | 18.7
2002 | 25.1 | 24.6 | 21.4 | 25.5 | 26.7 | 17.5
2003 | 24.1 | 23.7 | 21.2 | 24.6 | 25.2 | 16.6
2004 | 23.4 | 23.0 | 17.9 | 24.2 | 23.5 | 16.7
2005 | 23.9 | 23.4 | 19.6 | 24.2 | 26.1 | 20.4
2006 | 23.9 | 23.6 | 19.3 | 24.6 | 26.8 | 15.6
2007 | 22.3 | 22.0 | 17.4 | 23.6 | 23.7 | 14.5
2008 | 23.1 | 22.8 | 19.1 | 23.9 | 24.9 | 15.1
2009 | 23.5 | 23.2 | 17.7 | 25.0 | 23.3 | 16.4
2010 | 21.5 | 21.2 | 15.2 | 23.0 | 23.7 | 14.6
2011 | 21.6 | 21.2 | 16.5 | 22.6 | 23.6 | 14.2
2012 | 20.5 | 20.6 | 16.9 | 22.0 | 22.1 | 15.6
2013 | 20.5 | 20.5 | 16.7 | 21.8 | 21.7 | 14.6
2014 | 18.8 | 19.0 | 13.8 | 20.1 | 22.0 | 14.0
Women, 18 years and over
1999 | 21.5 | 21.6 | 11.9 | 23.8 | 20.5 | *6.3
2000 | 20.9 | 21.1 | 12.9 | 23.1 | 20.8 | 7.4
2001 | 20.6 | 20.7 | 11.5 | 23.5 | 17.8 | *6.0
2002 | 19.8 | 20.0 | 10.8 | 22.5 | 18.5 | 6.8
2003 | 19.2 | 19.4 | 10.4 | 22.1 | 18.1 | 6.0
2004 | 18.5 | 18.7 | 10.6 | 21.2 | 16.8 | *4.9
2005 | 18.1 | 18.3 | 10.9 | 20.8 | 17.1 | *5.9
2006 | 18.0 | 18.1 | 9.9 | 20.6 | 18.8 | 4.5
2007 | 17.4 | 17.5 | 8.4 | 20.7 | 15.5 | *3.8
2008 | 18.3 | 18.5 | 10.4 | 21.5 | 17.4 | 4.7
2009 | 17.9 | 18.1 | 9.5 | 20.7 | 18.9 | 7.3
2010 | 17.3 | 17.5 | 9.1 | 20.4 | 16.8 | 4.3
2011 | 16.5 | 16.8 | 8.3 | 19.8 | 15.3 | 5.5
2012 | 15.8 | 15.9 | 7.5 | 19.2 | 14.3 | 5.4
2013 | 15.3 | 15.5 | 6.8 | 18.6 | 15.1 | 4.6
2014 | 14.8 | 15.1 | 7.4 | 18.3 | 13.7 | 5.1
Men, 18 years and over | Standard error
1999 | 0.5 | 0.5 | 1.1 | 0.6 | 1.5 | 2.9
2000 | 0.5 | 0.4 | 1.1 | 0.5 | 1.2 | 2.1
2001 | 0.4 | 0.4 | 1.0 | 0.5 | 1.3 | 2.4
2002 | 0.5 | 0.4 | 1.0 | 0.5 | 1.3 | 2.1
2003 | 0.4 | 0.4 | 1.1 | 0.5 | 1.2 | 2.1
2004 | 0.4 | 0.4 | 0.9 | 0.5 | 1.2 | 2.1
2005 | 0.5 | 0.5 | 0.9 | 0.6 | 1.3 | 2.3
2006 | 0.5 | 0.5 | 1.2 | 0.7 | 1.6 | 1.6
2007 | 0.6 | 0.5 | 1.3 | 0.7 | 1.4 | 1.6
2008 | 0.6 | 0.6 | 1.3 | 0.7 | 1.5 | 1.9
2009 | 0.5 | 0.5 | 0.9 | 0.7 | 1.2 | 1.5
2010 | 0.5 | 0.5 | 0.9 | 0.6 | 1.1 | 1.6
2011 | 0.4 | 0.4 | 0.9 | 0.6 | 1.1 | 1.3
2012 | 0.4 | 0.4 | 0.9 | 0.6 | 1.1 | 1.4
2013 | 0.5 | 0.5 | 1.0 | 0.6 | 1.2 | 1.6
2014 | 0.4 | 0.4 | 0.8 | 0.6 | 1.1 | 1.6
Women, 18 years and over
1999 | 0.4 | 0.4 | 0.7 | 0.5 | 0.9 | 1.3
2000 | 0.4 | 0.4 | 0.8 | 0.5 | 0.9 | 1.4
2001 | 0.4 | 0.4 | 0.7 | 0.5 | 0.8 | 1.2
2002 | 0.4 | 0.4 | 0.7 | 0.5 | 0.9 | 1.3
2003 | 0.4 | 0.4 | 0.7 | 0.5 | 0.9 | 1.1
2004 | 0.4 | 0.4 | 0.7 | 0.5 | 0.9 | 1.1
2005 | 0.4 | 0.4 | 0.7 | 0.5 | 0.9 | 1.2
2006 | 0.4 | 0.4 | 0.8 | 0.6 | 1.0 | 0.8
2007 | 0.5 | 0.5 | 0.7 | 0.6 | 0.9 | 0.8
2008 | 0.5 | 0.5 | 0.8 | 0.7 | 1.0 | 0.8
2009 | 0.4 | 0.4 | 0.7 | 0.6 | 1.1 | 1.3
2010 | 0.4 | 0.4 | 0.6 | 0.6 | 0.9 | 0.7
2011 | 0.4 | 0.4 | 0.6 | 0.5 | 0.8 | 0.8
2012 | 0.4 | 0.4 | 0.6 | 0.5 | 0.7 | 0.8
2013 | 0.4 | 0.4 | 0.5 | 0.6 | 0.8 | 0.8
2014 | 0.4 | 0.4 | 0.5 | 0.7 | 0.8 | 0.9

Sex, age, and year 5 | Race and Hispanic origin 1
Sex, age, and year 5
Sex, age, and year 5 | Hispanic or Latino 3 | Not Hispanic or Latino 3
Sex, age, and year 5 | Hispanic or Latino 3
Sex, age, and year 5 | Hispanic or Latino 3 | White only | Black only | Asian only | American Indian or Alaska Native only | 2 or more races
Men, 18 years and over | Percent current smokers^4^
1999–2001 | 22.2 | 25.5 | 27.2 | 20.1 | 32.6 | 35.2
2003–2005 | 19.5 | 24.3 | 24.9 | 18.1 | 36.4 | 31.4
2006–2008 | 18.6 | 24.0 | 25.1 | 15.2 | 39.2 | 24.8
2009–2011 | 16.4 | 23.5 | 23.5 | 15.0 | 31.1 | 28.9
2012–2014 | 15.7 | 21.3 | 21.9 | 14.8 | 28.0 | 29.8
Women, 18 years and over
1999–2001 | 12.1 | 23.5 | 19.7 | 6.6 | 36.3 | 31.6
2003–2005 | 10.6 | 21.4 | 17.3 | 5.6 | 29.0 | 27.0
2006–2008 | 9.5 | 20.9 | 17.2 | 4.3 | 28.2 | 25.9
2009–2011 | 9.0 | 20.3 | 17.0 | 5.6 | 26.2 | 24.8
2012–2014 | 7.3 | 18.7 | 14.4 | 5.0 | 24.0 | 25.1
Men, 18 years and over | Standard error
1999–2001 | 0.6 | 0.3 | 0.8 | 1.4 | 4.4 | 2.6
2003–2005 | 0.6 | 0.3 | 0.8 | 1.3 | 3.8 | 2.7
2006–2008 | 0.7 | 0.4 | 0.9 | 1.0 | 5.7 | 2.7
2009–2011 | 0.5 | 0.4 | 0.7 | 0.9 | 4.6 | 2.6
2012–2014 | 0.5 | 0.4 | 0.7 | 0.9 | 3.5 | 2.2
Women, 18 years and over
1999–2001 | 0.4 | 0.3 | 0.5 | 0.7 | 3.5 | 2.5
2003–2005 | 0.4 | 0.3 | 0.5 | 0.7 | 3.6 | 2.4
2006–2008 | 0.4 | 0.4 | 0.6 | 0.5 | 3.8 | 2.4
2009–2011 | 0.4 | 0.4 | 0.6 | 0.6 | 3.4 | 2.0
2012–2014 | 0.3 | 0.3 | 0.5 | 0.5 | 3.2 | 2.1

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error of 20%-30%.

1 Persons of Hispanic origin may be of any race. Race-specific estimates are tabulated according to the 1997 Revisions to the Standards for the Classification of Federal Data on Race and Ethnicity. The single-race categories plus multiple-race category shown in the table conform to the 1997 Standards. Starting with 2003 data, race responses of other race and unspecified multiple race were treated as missing, and then race was imputed if these were the only race responses. Almost all persons with a race response of other race were of Hispanic origin. See Appendix II, Hispanic origin; Race.

2 Includes all persons not shown separately.

3 Estimates are age-adjusted to the year 2000 standard population using five age groups: 18–24 years, 25–34 years, 35–44 years, 45–64 years, and 65 years and over. Age-adjusted estimates in this table may differ from other age-adjusted estimates based on the same data and presented elsewhere if different age groups are used in the adjustment procedure. See Appendix II, Age adjustment.

4 Current cigarette smokers are defined as ever smoking 100 cigarettes in their lifetime and now smoke every day or some days. See Appendix II, Cigarette smoking.

5 Three-year average annual estimates are shown in order to present estimates for the American Indian or Alaska Native and the multiple-race populations. Annual estimates are not stable for smaller population groups.

NOTES: Ties in highest and lowest rates were resolved by looking at additional decimal places. See Technical Notes. Also see Figure 7.

SOURCE: CDC/NCHS, National Health Interview Survey. Family core and sample adult questionnaires. See Appendix I, National Health Interview Survey (NHIS).

Data table for Figure 25 Influenza vaccination among adults aged 18 and over, by age and race and Hispanic origin: United States, 1999–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig25

Age and year | Total 2 | Race and Hispanic origin 1
Age and year | Total 2
Age and year | Total 2 | Hispanic or Latino | Not Hispanic or Latino
Age and year | Total 2 | Hispanic or Latino
Age and year | Total 2 | Hispanic or Latino | White only | Black only | Asian only
18–64 years | Percent with influenza vaccination in the past year^3^
1999 | 20.6 | 15.0 | 21.9 | 17.7 | 19.5
2000 | 21.4 | 14.6 | 23.2 | 16.2 | 23.8
2001 | 19.3 | 13.3 | 20.8 | 16.8 | 18.3
2002 | 20.8 | 14.3 | 22.2 | 18.4 | 21.7
2003 | 22.1 | 14.1 | 24.1 | 19.3 | 20.1
2004 | 22.7 | 14.3 | 25.3 | 17.0 | 23.3
2005 | 14.1 | 9.5 | 15.5 | 12.4 | 11.3
2006 | 20.5 | 13.5 | 22.4 | 18.1 | 21.1
2007 | 23.0 | 16.2 | 25.3 | 17.9 | 24.0
2008 | 25.8 | 17.6 | 28.2 | 22.3 | 25.8
2009 | 28.3 | 20.7 | 30.7 | 24.4 | 31.4
2010 | 30.1 | 23.8 | 32.2 | 24.6 | 35.0
2011 | 31.9 | 26.1 | 34.0 | 27.7 | 34.7
2012 | 31.5 | 25.2 | 33.4 | 27.5 | 37.5
2013 | 35.0 | 26.1 | 37.8 | 29.6 | 40.9
2014 | 35.8 | 27.9 | 38.5 | 30.8 | 41.3
65 years and over
1999 | 65.7 | 55.1 | 67.9 | 49.7 | 71.7
2000 | 64.4 | 55.7 | 66.6 | 48.0 | 58.6
2001 | 63.1 | 51.8 | 65.4 | 47.9 | 58.6
2002 | 65.7 | 48.5 | 68.7 | 49.4 | 58.4
2003 | 65.5 | 45.4 | 68.6 | 47.8 | 63.3
2004 | 64.6 | 54.6 | 67.3 | 45.6 | 59.0
2005 | 59.7 | 41.7 | 63.2 | 39.6 | 58.9
2006 | 64.3 | 44.9 | 67.4 | 47.1 | 67.9
2007 | 66.7 | 52.3 | 69.4 | 55.4 | 63.4
2008 | 67.2 | 54.9 | 70.0 | 50.9 | 68.5
2009 | 66.8 | 57.0 | 69.0 | 52.9 | 68.9
2010 | 63.9 | 54.6 | 65.9 | 52.8 | 67.3
2011 | 66.9 | 57.3 | 69.0 | 53.4 | 69.5
2012 | 66.5 | 57.8 | 68.9 | 53.2 | 65.2
2013 | 67.9 | 57.2 | 70.2 | 55.9 | 70.0
2014 | 70.1 | 60.8 | 72.4 | 57.4 | 72.7
| Standard error
18–64 years
1999 | 0.3 | 0.7 | 0.4 | 0.8 | 1.7
2000 | 0.3 | 0.7 | 0.4 | 0.7 | 1.9
2001 | 0.3 | 0.6 | 0.4 | 0.8 | 1.5
2002 | 0.3 | 0.7 | 0.4 | 0.8 | 1.7
2003 | 0.3 | 0.6 | 0.4 | 0.8 | 1.6
2004 | 0.3 | 0.6 | 0.4 | 0.8 | 1.7
2005 | 0.3 | 0.5 | 0.3 | 0.7 | 1.3
2006 | 0.4 | 0.7 | 0.5 | 0.9 | 1.5
2007 | 0.4 | 0.8 | 0.6 | 0.9 | 1.8
2008 | 0.4 | 0.8 | 0.5 | 1.0 | 1.7
2009 | 0.4 | 0.8 | 0.5 | 1.1 | 1.8
2010 | 0.4 | 0.8 | 0.6 | 0.9 | 1.6
2011 | 0.4 | 0.8 | 0.5 | 0.9 | 1.4
2012 | 0.4 | 0.8 | 0.5 | 0.9 | 1.6
2013 | 0.4 | 0.8 | 0.5 | 1.0 | 1.6
2014 | 0.4 | 0.9 | 0.6 | 1.0 | 1.6
65 years and over
1999 | 0.8 | 2.7 | 0.8 | 2.3 | 5.9
2000 | 0.7 | 2.6 | 0.8 | 2.3 | 5.9
2001 | 0.7 | 2.6 | 0.8 | 2.4 | 6.2
2002 | 0.7 | 2.7 | 0.8 | 2.3 | 5.5
2003 | 0.7 | 2.7 | 0.8 | 2.3 | 6.0
2004 | 0.7 | 2.7 | 0.8 | 2.4 | 6.0
2005 | 0.8 | 2.8 | 0.8 | 2.1 | 4.7
2006 | 0.9 | 2.9 | 1.1 | 2.3 | 3.9
2007 | 0.8 | 3.1 | 1.0 | 2.3 | 4.5
2008 | 0.9 | 3.1 | 1.0 | 2.5 | 3.7
2009 | 0.8 | 2.9 | 0.9 | 2.3 | 3.3
2010 | 0.8 | 2.6 | 0.9 | 2.1 | 3.5
2011 | 0.7 | 2.2 | 0.8 | 1.8 | 3.4
2012 | 0.8 | 2.3 | 0.9 | 2.1 | 3.2
2013 | 0.7 | 2.2 | 0.9 | 2.0 | 3.4
2014 | 0.7 | 2.2 | 0.8 | 2.0 | 2.8

Age and year 4 | Race and Hispanic origin 1
Age and year 4
Age and year 4 | Hispanic or Latino | Not Hispanic or Latino
Age and year 4 | Hispanic or Latino
Age and year 4 | Hispanic or Latino | White only | Black only | Asian only | American Indian or Alaska Native | 2 or more races
| Percent with influenza vaccination in the past year^3^
18–64 years
1999–2001 | 14.3 | 22.0 | 16.9 | 20.5 | 24.1 | 20.2
2003–2005 | 12.6 | 21.6 | 16.2 | 18.1 | 20.9 | 20.8
2006–2008 | 15.8 | 25.3 | 19.4 | 23.6 | 26.8 | 24.5
2009–2011 | 23.6 | 32.3 | 25.5 | 33.7 | 33.4 | 24.8
2012–2014 | 26.4 | 36.5 | 29.3 | 39.9 | 43.0 | 30.8
65 years and over
1999–2001 | 54.2 | 66.6 | 48.5 | 62.8 | 54.9 | 67.5
2003–2005 | 47.2 | 66.4 | 44.3 | 60.2 | 60.4 | 63.6
2006–2008 | 50.9 | 68.9 | 51.1 | 66.8 | 69.9 | 59.2
2009–2011 | 56.3 | 68.0 | 53.0 | 68.6 | 63.0 | 71.9
2012–2014 | 58.7 | 70.6 | 55.6 | 69.5 | 65.1 | 56.5
| Standard error
18–64 years
1999–2001 | 0.4 | 0.2 | 0.4 | 1.0 | 2.2 | 1.7
2003–2005 | 0.4 | 0.2 | 0.4 | 0.9 | 2.4 | 1.7
2006–2008 | 0.5 | 0.4 | 0.5 | 1.0 | 4.5 | 2.1
2009–2011 | 0.5 | 0.3 | 0.5 | 0.9 | 3.1 | 1.7
2012–2014 | 0.5 | 0.3 | 0.5 | 0.9 | 3.1 | 1.7
65 years and over
1999–2001 | 1.6 | 0.5 | 1.4 | 3.6 | 8.1 | 5.2
2003–2005 | 1.6 | 0.5 | 1.4 | 3.2 | 7.7 | 5.3
2006–2008 | 1.7 | 0.6 | 1.4 | 2.4 | 6.5 | 5.2
2009–2011 | 1.5 | 0.5 | 1.2 | 2.1 | 7.9 | 4.4
2012–2014 | 1.3 | 0.5 | 1.2 | 1.9 | 6.1 | 4.1

1 Persons of Hispanic origin may be of any race. Race-specific estimates are tabulated according to the 1997 Revisions to the Standards for the Classification of Federal Data on Race and Ethnicity. The single-race categories plus multiple-race category shown in the table conform to the 1997 Standards. Starting with 2003 data, race responses of other race and unspecified multiple race were treated as missing, and then race was imputed if these were the only race responses. Almost all persons with a race response of other race were of Hispanic origin. See Appendix II, Hispanic origin; Race.

2 Includes all persons not shown separately.

3 Influenza vaccination is based on respondent report of receipt of a seasonal flu shot or influenza nasal spray (starting in 2005). Questions concerning use of influenza vaccination differed slightly on the National Health Interview Survey across the years for which data are shown. See Appendix II, Vaccination.

4 Three-year average annual estimates are shown in order to present estimates for the American Indian or Alaska Native and the multiple-race populations. Annual estimates are not stable for smaller population groups.

NOTES: Also see Table 68. Ties in highest and lowest rates were resolved by looking at additional decimal places. See Technical Notes. Prevalence of influenza vaccination during the past 12 months is different from season-specific coverage, see: CDC. (2013). Surveillance of influenza vaccination coverage—United States, 2007–08 through 2011–12 influenza seasons. MMWR. ; and CDC. FluVaxView. Available from: http://www.cdc.gov/flu/fluvaxview/. The recommendations of the Advisory Committee on Immunization Practices regarding who should receive an influenza vaccination have changed over the years, and changes in coverage estimates may reflect changes in recommendations. An influenza vaccine shortage occurred during the 2004–2005 influenza season. Delays in the availability of influenza shots also occurred in fall 2000 and, to a lesser extent, in fall 2001.

SOURCE: CDC/NCHS, National Health Interview Survey. Family core and sample adult questionnaires. See Appendix I, National Health Interview Survey (NHIS).

Data table for Figure 26 No health insurance coverage among persons under age 65, by age and race and Hispanic origin: United States, 1999–June 2015 (preliminary data)

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig26

Age and year | Total 2 | Race and Hispanic origin 1
Age and year | Total 2
Age and year | Total 2 | Hispanic or Latino | Not Hispanic or Latino
Age and year | Total 2 | Hispanic or Latino
Age and year | Total 2 | Hispanic or Latino | White only | Black only | Asian only
| Percent without health insurance coverage^3^
Under 18 years
1999 | 11.9 | 26.7 | 8.1 | 11.9 | 10.4
2000 | 12.6 | 25.9 | 8.7 | 12.2 | 12.5
2001 | 11.2 | 24.6 | 7.2 | 10.6 | 12.6
2002 | 10.9 | 21.9 | 7.5 | 10.0 | 13.4
2003 | 9.8 | 20.2 | 6.4 | 8.9 | 12.0
2004 | 9.2 | 19.5 | 6.4 | 6.9 | 10.5
2005 | 9.3 | 17.5 | 6.5 | 8.9 | 11.4
2006 | 9.5 | 19.4 | 6.2 | 7.8 | 8.3
2007 | 9.0 | 15.3 | 7.1 | 6.2 | 8.0
2008 | 9.0 | 16.8 | 6.7 | 7.5 | 6.5
2009 | 8.2 | 14.7 | 6.0 | 6.6 | 7.5
2010 | 7.8 | 13.0 | 5.8 | 6.4 | 8.7
2011 | 7.0 | 12.3 | 4.8 | 5.5 | 7.8
2012 | 6.6 | 10.9 | 5.2 | 4.4 | 7.8
2013 | 6.6 | 11.8 | 4.7 | 5.1 | 5.9
2014 | 5.4 | 9.7 | 4.1 | 3.5 | *4.3
2015, Jan–Jun^4^ | 4.5 | 8.0 | 3.6 | 2.9 | *
18–64 years
1999 | 17.9 | 38.5 | 13.6 | 23.0 | 19.1
2000 | 18.9 | 41.4 | 13.9 | 23.6 | 19.5
2001 | 18.5 | 41.1 | 13.5 | 23.0 | 18.9
2002 | 19.3 | 40.8 | 14.4 | 23.2 | 18.7
2003 | 19.3 | 42.8 | 13.9 | 22.9 | 20.3
2004 | 19.3 | 42.9 | 14.0 | 22.7 | 18.6
2005 | 19.3 | 41.8 | 13.9 | 23.1 | 18.9
2006 | 20.0 | 43.8 | 14.6 | 22.2 | 16.5
2007 | 19.6 | 41.1 | 14.4 | 22.0 | 16.9
2008 | 19.9 | 42.6 | 14.4 | 22.9 | 15.7
2009 | 21.2 | 43.4 | 15.6 | 24.4 | 17.8
2010 | 22.3 | 43.3 | 16.3 | 27.1 | 19.4
2011 | 21.2 | 42.1 | 15.6 | 24.6 | 18.8
2012 | 20.9 | 41.3 | 15.1 | 23.6 | 19.1
2013 | 20.5 | 41.1 | 14.5 | 24.7 | 16.1
2014 | 16.3 | 34.1 | 11.5 | 17.6 | 12.1
2015, Jan–Jun^4^ | 12.7 | 27.2 | 8.8 | 14.5 | 7.3
| Standard error
Under 18 years
1999 | 0.3 | 0.9 | 0.4 | 0.8 | 1.5
2000 | 0.3 | 0.9 | 0.4 | 0.8 | 1.9
2001 | 0.4 | 0.9 | 0.4 | 0.9 | 2.1
2002 | 0.3 | 0.8 | 0.4 | 0.8 | 1.9
2003 | 0.3 | 0.8 | 0.4 | 0.7 | 2.1
2004 | 0.3 | 0.8 | 0.4 | 0.6 | 1.8
2005 | 0.3 | 0.7 | 0.4 | 0.7 | 1.9
2006 | 0.3 | 0.9 | 0.4 | 0.7 | 1.3
2007 | 0.4 | 0.8 | 0.5 | 0.6 | 1.4
2008 | 0.4 | 0.8 | 0.6 | 0.8 | 1.1
2009 | 0.4 | 0.8 | 0.5 | 0.6 | 1.1
2010 | 0.3 | 0.6 | 0.3 | 0.6 | 1.1
2011 | 0.3 | 0.6 | 0.3 | 0.6 | 1.1
2012 | 0.3 | 0.6 | 0.3 | 0.5 | 1.4
2013 | 0.3 | 0.6 | 0.3 | 0.6 | 1.0
2014 | 0.2 | 0.5 | 0.3 | 0.4 | 0.9
2015, Jan–Jun^4^ | 0.4 | 0.7 | 0.5 | 0.6 | *
18–64 years
1999 | 0.3 | 0.8 | 0.3 | 0.7 | 1.4
2000 | 0.3 | 0.9 | 0.3 | 0.7 | 1.4
2001 | 0.3 | 0.8 | 0.3 | 0.7 | 1.3
2002 | 0.3 | 0.8 | 0.3 | 0.7 | 1.3
2003 | 0.3 | 0.8 | 0.3 | 0.7 | 1.4
2004 | 0.3 | 0.8 | 0.3 | 0.6 | 1.4
2005 | 0.3 | 0.7 | 0.3 | 0.7 | 1.2
2006 | 0.3 | 0.9 | 0.3 | 0.7 | 1.1
2007 | 0.3 | 0.8 | 0.3 | 0.7 | 1.1
2008 | 0.3 | 0.9 | 0.3 | 0.7 | 1.0
2009 | 0.3 | 0.9 | 0.3 | 0.7 | 1.1
2010 | 0.3 | 0.8 | 0.4 | 0.7 | 0.9
2011 | 0.3 | 0.7 | 0.3 | 0.6 | 0.9
2012 | 0.3 | 0.7 | 0.3 | 0.7 | 1.0
2013 | 0.3 | 0.8 | 0.3 | 0.6 | 0.8
2014 | 0.3 | 0.7 | 0.3 | 0.6 | 0.7
2015, Jan–Jun^4^ | 0.3 | 0.9 | 0.3 | 0.7 | 0.6

Age and year 5 | Race and Hispanic origin 1
Age and year 5
Age and year 5 | Hispanic or Latino | Not Hispanic or Latino
Age and year 5 | Hispanic or Latino
Age and year 5 | Hispanic or Latino | White only | Black only | Asian only | American Indian or Alaska Native only | 2 or more races
| Percent without health insurance coverage^3^
Under 18 years
1999–2001 | 25.7 | 8.0 | 11.6 | 11.9 | 34.1 | 10.3
2003–2005 | 19.1 | 6.4 | 8.2 | 11.3 | 31.6 | 6.3
2006–2008 | 17.1 | 6.7 | 7.2 | 7.6 | *24.2 | 9.2
2009–2011 | 13.3 | 5.5 | 6.2 | 8.0 | *26.1 | 6.0
2012–2014 | 10.8 | 4.7 | 4.3 | 5.9 | 13.8 | 4.6
18–64 years
1999–2001 | 40.4 | 13.7 | 23.2 | 19.2 | 39.8 | 21.1
2003–2005 | 42.5 | 13.9 | 22.9 | 19.2 | 36.9 | 21.1
2006–2008 | 42.5 | 14.5 | 22.4 | 16.4 | 39.1 | 22.4
2009–2011 | 42.9 | 15.8 | 25.4 | 18.7 | 39.9 | 25.3
2012–2014 | 38.8 | 13.7 | 22.0 | 15.7 | 33.2 | 19.4
| Standard error
Under 18 years
1999–2001 | 0.6 | 0.2 | 0.5 | 1.1 | 4.0 | 1.1
2003–2005 | 0.5 | 0.2 | 0.4 | 1.1 | 4.0 | 0.9
2006–2008 | 0.5 | 0.3 | 0.4 | 0.8 | 7.2 | 1.0
2009–2011 | 0.4 | 0.2 | 0.4 | 0.7 | 7.3 | 0.7
2012–2014 | 0.4 | 0.2 | 0.3 | 0.7 | 2.6 | 0.5
18–64 years
1999–2001 | 0.6 | 0.2 | 0.4 | 0.8 | 3.2 | 1.3
2003–2005 | 0.5 | 0.2 | 0.4 | 0.8 | 2.7 | 1.3
2006–2008 | 0.6 | 0.2 | 0.4 | 0.7 | 5.8 | 1.2
2009–2011 | 0.5 | 0.2 | 0.4 | 0.6 | 6.0 | 1.2
2012–2014 | 0.6 | 0.2 | 0.4 | 0.5 | 2.8 | 1.0

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error (RSE) of 20%-30%. Data not shown have an RSE greater than 30%.

1 Persons of Hispanic origin may be of any race. Race-specific estimates are tabulated according to the 1997 Revisions to the Standards for the Classification of Federal Data on Race and Ethnicity. The single-race categories plus multiple-race category shown in the table conform to the 1997 Standards. Starting with 2003 data, race responses of other race and unspecified multiple race were treated as missing, and then race was imputed if these were the only race responses. Almost all persons with a race response of other race were of Hispanic origin. See Appendix II, Hispanic origin; Race.

2 Includes all persons not shown separately.

3 Persons not covered by private insurance, Medicaid, Children's Health Insurance Program (CHIP), state-sponsored or other government-sponsored health plans (starting in 1997), Medicare, or military plans are considered to have no health insurance coverage. Persons with only Indian Health Service coverage are considered to have no health insurance coverage. Health insurance coverage is at the time of interview.

4 Preliminary data based on the National Health Interview Survey's Early Release program. Estimates based on the preliminary 6-month file may differ from estimates based on the final annual file and have larger standard errors associated with them than standard errors based on a final annual file. Available from: Martinez ME, Cohen RA. (2015). Health insurance coverage: Early release of estimates from the National Health Interview Survey, January–June 2015. and National Health Interview Survey, 2015 preliminary file. For more information, visit: http://www.cdc.gov/nchs/nhis.htm.

5 Three-year average annual estimates are shown in order to present estimates for the American Indian or Alaska Native and the multiple-race populations. Annual estimates are not stable for smaller population groups.

NOTES: Also see Tables 102–105 and Figure 16. Ties in highest and lowest rates were resolved by looking at additional decimal places. See Technical Notes.

SOURCE: CDC/NCHS, National Health Interview Survey. Family core and sample adult questionnaires. See Appendix I, National Health Interview Survey (NHIS).

Data table for Figure 27 Nonreceipt of needed dental care in the past 12 months due to cost among adults aged 18–64, by race and Hispanic origin: United States, 1999–2014

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2015.htm#fig27

Age and year | Total 2 | Race and Hispanic origin 1
Age and year | Total 2
Age and year | Total 2 | Hispanic or Latino | Not Hispanic or Latino
Age and year | Total 2 | Hispanic or Latino
Age and year | Total 2 | Hispanic or Latino | White only | Black only | Asian only
| Percent who did not receive needed dental care in the past 12 months due to cost^3^
18–64 years
1999 | 9.3 | 8.5 | 9.3 | 10.4 | 4.5
2000 | 9.7 | 9.8 | 9.8 | 10.1 | 5.3
2001 | 10.4 | 12.0 | 10.2 | 10.3 | 5.1
2002 | 10.4 | 11.1 | 10.0 | 12.4 | 7.4
2003 | 11.5 | 13.5 | 11.1 | 12.8 | 5.3
2004 | 13.2 | 15.8 | 12.9 | 14.1 | 5.4
2005 | 13.0 | 15.5 | 12.3 | 15.3 | 6.8
2006 | 13.6 | 16.5 | 12.9 | 16.0 | 6.6
2007 | 13.0 | 16.0 | 12.5 | 13.6 | 7.5
2008 | 15.9 | 20.8 | 14.9 | 18.2 | 7.8
2009 | 16.8 | 22.2 | 15.5 | 19.0 | 9.1
2010 | 17.3 | 21.6 | 16.2 | 20.8 | 8.4
2011 | 16.4 | 21.1 | 15.4 | 18.2 | 9.4
2012 | 14.8 | 18.3 | 13.7 | 17.0 | 10.4
2013 | 14.3 | 18.4 | 13.3 | 16.3 | 8.8
2014 | 12.6 | 15.7 | 11.9 | 14.6 | 6.3
| Standard error
1999 | 0.2 | 0.5 | 0.3 | 0.7 | 0.9
2000 | 0.2 | 0.6 | 0.3 | 0.6 | 0.9
2001 | 0.2 | 0.6 | 0.3 | 0.6 | 0.9
2002 | 0.2 | 0.6 | 0.3 | 0.8 | 1.1
2003 | 0.3 | 0.7 | 0.3 | 0.7 | 0.9
2004 | 0.3 | 0.7 | 0.3 | 0.7 | 0.8
2005 | 0.3 | 0.6 | 0.3 | 0.8 | 1.0
2006 | 0.3 | 0.8 | 0.4 | 0.9 | 1.0
2007 | 0.3 | 0.8 | 0.4 | 0.8 | 0.9
2008 | 0.4 | 1.1 | 0.5 | 0.9 | 1.0
2009 | 0.4 | 1.0 | 0.5 | 0.9 | 1.0
2010 | 0.3 | 0.8 | 0.4 | 0.8 | 0.9
2011 | 0.3 | 0.7 | 0.4 | 0.8 | 0.9
2012 | 0.3 | 0.7 | 0.4 | 0.8 | 1.0
2013 | 0.3 | 0.7 | 0.4 | 0.7 | 0.9
2014 | 0.3 | 0.6 | 0.4 | 0.8 | 0.7

Age and year 4 | Race and Hispanic origin 1
Age and year 4
Age and year 4 | Hispanic or Latino | Not Hispanic or Latino
Age and year 4 | Hispanic or Latino
Age and year 4 | Hispanic or Latino | White only | Black only | Asian only | American Indian or Alaska Native only | 2 or more races
| Percent who did not receive needed dental care in the past 12 months due to cost^3^
18–64 years
1999–2001 | 10.2 | 9.8 | 10.3 | 5.0 | 11.6 | 18.7
2003–2005 | 14.9 | 12.1 | 14.1 | 5.8 | 18.9 | 19.5
2006–2008 | 17.8 | 13.5 | 15.9 | 7.3 | 15.8 | 21.7
2009–2011 | 21.6 | 15.7 | 19.4 | 9.0 | 19.6 | 25.2
2012–2014 | 17.4 | 12.9 | 16.0 | 8.5 | 11.1 | 19.5
| Standard error
1999–2001 | 0.3 | 0.2 | 0.4 | 0.5 | 1.7 | 1.7
2003–2005 | 0.4 | 0.2 | 0.4 | 0.5 | 2.8 | 1.6
2006–2008 | 0.5 | 0.3 | 0.5 | 0.6 | 3.0 | 2.0
2009–2011 | 0.5 | 0.3 | 0.5 | 0.5 | 2.6 | 1.8
2012–2014 | 0.4 | 0.3 | 0.5 | 0.5 | 1.9 | 1.5

1 Persons of Hispanic origin may be of any race. Race-specific estimates are tabulated according to the 1997 Revisions to the Standards for the Classification of Federal Data on Race and Ethnicity. The single-race categories plus multiple-race category shown in the table conform to the 1997 Standards. Starting with 2003 data, race responses of other race and unspecified multiple race were treated as missing, and then race was imputed if these were the only race responses. Almost all persons with a race response of other race were of Hispanic origin. See Appendix II, Hispanic origin; Race.

2 Includes all persons not shown separately.

3 Based on persons responding to the question, “During the past 12 months was there any time when [person] needed dental care (including checkups) but didn't get it because [person] couldn't afford it?”

4 Three-year average annual estimates are shown in order to present estimates for the American Indian or Alaska Native and the multiple-race populations. Annual estimates are not stable for smaller population groups.

NOTE: Also see Table 63.

SOURCE: CDC/NCHS, National Health Interview Survey. Family core and sample adult questionnaires. See Appendix I, National Health Interview Survey (NHIS).

## Technical Notes

### Data Sources

Data for the Health, United States, 2015 Chartbook come from many surveys and data systems and cover a broad range of years. Detailed descriptions of the data sources included in the Chartbook are provided in Appendix I. Data Sources. Additional information clarifying and qualifying the data is included in the table notes and in Appendix II. Definitions and Methods.

### Data Presentation

Many measures in the Chartbook are shown for people in specific age groups because of the strong effect of age on most health outcomes. Age-adjusted rates and age-adjusted percentages are computed to eliminate differences in observed rates that result from age differences in population composition (see Appendix II, Age adjustment). Age-adjusted rates and age-adjusted percentages are noted as such in the text; rates and percentages without this notation are crude rates and crude percentages. For some charts, data years are combined to increase sample size and the reliability of the estimates. Some charts present time trends, and others focus on differences in estimates among population subgroups for the most recent time point available. Figures 1–17 and the Highlights section generally present trends for the recent 10-year period. For some indicators, a slightly longer or shorter period may be shown due to design or data comparability issues. Trends are generally shown on a linear scale to emphasize absolute differences over time. The time trends for the overall mortality measures are shown on a logarithmic (log) scale to enable measures with large differences in magnitude to be shown on the same chart.

Point estimates and standard errors for Figures 1–17 are available either in the Trend Table and Excel spreadsheet specified in the note below the chart, or in the Chartbook tables section. For the Special Feature on racial and ethnic health disparities (Figures 18–27), data tables with point estimates and standard errors are contained in the Chartbook tables section. These data tables may include additional data that were not graphed because of space considerations.

### Reliability of Estimates

Overall estimates generally have relatively small sampling errors, but estimates for certain population subgroups may be based on small numbers and have relatively large sampling errors. Numbers of deaths obtained from the National Vital Statistics System represent complete counts and therefore are not subject to sampling error. They are, however, subject to random variation, which means that the number of events that actually occur in a given year may be considered as one of a large series of possible results that could have arisen under the same circumstances. When the number of events is small and the probability of such an event is small, considerable caution must be observed in interpreting the conditions described by the charts. Estimates that are unreliable because of large sampling errors or small numbers of events have been noted with an asterisk. The criteria used to designate or suppress unreliable estimates are indicated in the notes to the applicable tables or charts.

For NCHS surveys, point estimates and their corresponding variances were calculated using the SUDAAN software package, which takes into consideration the complex survey design (94). Standard errors for other surveys or data sets were computed using the methodology recommended by the programs providing the data, or were provided directly by those programs.

### Statistical Testing

Data trends can be described in many ways. For most trend analyses presented in the Chartbook, increases or decreases in the estimates during the entire time period shown are assessed by the weighted least squares regression method in the National Cancer Institute's Joinpoint software (with Grid search and Bayesian Information Criterion (BIC) model selection). The default maximum number of joinpoints based on the number of available data points in the trend was used. Statistically significant changes in the trend were assessed at the 0.05 level. For more information on Joinpoint, see: http://surveillance.cancer.gov/joinpoint. Statistical significance of differences between regression coefficients at the 0.05 level was also taken into account to select a model with the fewest joinpoints or changes in trend. For some trend charts, there were too few observations for Joinpoint analysis. In those cases, either the difference between two points was assessed for statistical significance using z-tests or the statistical testing methods recommended by the data systems were used. Trend analyses using weighted least squares regression for Figures 1–17 were carried out on the log scale so that results provide estimates of percent change. However, as discussed below, trend analyses for figures in the Special Feature were carried out on the linear scale.

For analyses that show two time points, differences between the two points were assessed for statistical significance at the 0.05 level using two-sided significance tests (z-tests) without correction for multiple comparisons. Trend and data tables include point estimates and standard errors for users who would like to perform additional statistical tests.

Terms such as “similar,”“stable,” and“no difference” used in the text indicate that the statistics being compared were not significantly different. Lack of comment regarding the difference between statistics does not necessarily suggest that the difference was tested and found to be not significant. Because statistically significant differences or trends are partly a function of sample size (the larger the sample, the smaller the change that can be detected), they do not necessarily have public health significance (95).

### Special Feature on Racial and Ethnic Health Disparities (Figures 18–27)

In general, the starting time period for trend analysis in the Special Feature is 1999. This is the earliest year for which National Health Interview Survey (NHIS) data were available for detailed racial and ethnic groups (see Appendix II, Race). Trend data on race and ethnicity are presented in the greatest detail possible after taking into account the quality of the data, the amount of missing data, and the number of observations. These issues significantly affect the availability of reportable data for certain populations, such as the Native Hawaiian or Other Pacific Islander population and the American Indian or Alaska Native population. Estimates for the Native Hawaiian or Other Pacific Islander population were unstable and are not presented. Three years of data were combined in order to present estimates for the American Indian or Alaska Native population in the data tables that accompany Figures 24–27.

There are various ways to quantify racial and ethnic differences in health and mortality, and different measures of disparity may lead to different conclusions (55–58). This Special Feature uses the maximal rate difference, one of three overall measures used in Healthy People 2020, to measure racial and ethnic disparities (59). The maximal rate difference is an overall measure of health disparities calculated as the absolute difference between the highest and lowest group rates in the population for a given characteristic, irrespective of other, intermediate rates (59). A decrease in the maximal rate difference does not capture whether the population health outcome overall is improving; rather it reflects progress toward eliminating disparities. As the absolute difference between the highest and lowest rates decreases toward 0, all the pairwise absolute differences between population subgroups will tend to 0. For determination of the highest and lowest group rates, estimates were ranked from highest to lowest based on the observed value to six decimal places, to avoid ties. Tests of statistical significance against other rates were not conducted. For consistency with the use of the absolute difference to measure disparity, all analyses in the Special Feature are carried out on the linear scale. For each figure in the Special Feature that shows trends (Figures 19, 21, 23–27) the following analyses were carried out:

a. trend analysis of overall estimates;
b. trend analysis of estimates for each racial and ethnic group; and
c. trend analysis of the maximal rate difference.

These trend analyses provide information used to:

a. describe the trend in overall estimates as increasing, decreasing, or stable, and any changes in trend over the time period;
b. indicate whether the trend in estimates for different racial and ethnic groups is similar to the overall trend; and
c. describe the trend in disparity as measured by the maximal difference in rates as increasing, decreasing, or stable and any changes in trend over the time period.

In addition, a one-sided z-test was conducted to test whether the maximal difference in rates was 0 vs. >0 at the most recent time point (59). For figures in the Special Feature that only show estimates at a single time point, the maximal rate difference was calculated for that time point, and a one-sided z-test was conducted to test whether the maximal difference in rates was 0 vs. >0.

## References

1 Xu JQ, Murphy SL, Kochanek KD, Bastian BA. (2016). Deaths: Final data for 2013. National vital statistics reports.
2 Heron M. (2016). Deaths: Leading causes for 2013. National vital statistics reports.
3 HHS, National Action Alliance for Suicide Prevention. (2012). 2012 National strategy for suicide prevention: Goals and objectives for action: A report of the U.S. Surgeon General and of the National Action Alliance for Suicide Prevention.
4 Institute of Medicine. (2002). Reducing suicide: A national imperative.
5 Rheingold AA, Zinzow H, Hawkins A, Saunders BE, Kilpatrick DG. (2012). Prevalence and mental health outcomes of homicide survivors in a representative U.S. sample of adolescents: Data from the 2005 National Survey of Adolescents. J Child Psychol Psychiatry.
6 Smith EL, Cooper A. (2013). Homicide in the U.S. known to law enforcement, 2011.
7 Swanson JW, Bonnie RJ, Appelbaum PS. (2015). Getting serious about reducing suicide: More “how” and less “why”. JAMA.
8 Martin JA, Hamilton BE, Osterman MJK. (2015). Births in the United States, 2014.
9 Ventura SJ, Hamilton BE, Mathews TJ. (2014). National and state patterns of teen births in the United States, 1940–2013. National vital statistics reports.
10 Adams D, Fullerton K, Jajosky R, et al. (2015). Summary of notifiable infectious diseases and conditions—United States, 2013. MMWR.
11 CDC. (2015). National Notifiable Diseases Surveillance System (NNDSS): History and background.
12 HHS. (2010). How tobacco smoke causes disease: The biology and behavioral basis for smoking-attributable disease: A report of the Surgeon General.
13 Freedman DS, Mei Z, Srinivasan SR, Berenson GS, Dietz WH. (2007). Cardiovascular risk factors and excess adiposity among overweight children and adolescents: The Bogalusa Heart Study. J Pediatr.
14 Engeland A, Bjørge T, Tverdal A, Søgaard AJ. (2004). Obesity in adolescence and adulthood and the risk of adult mortality. Epidemiology.
15 Kuczmarski RJ, Ogden CL, Guo SS, et al. (2002). 2000 CDC growth charts for the United States: Methods and development. NCHS. Vital Health Stat.
16 Barlow SE, Expert Committee. (2007). Expert Committee recommendations regarding the prevention, assessment, and treatment of child and adolescent overweight and obesity: Summary report. Pediatrics.
17 National Heart, Lung, and Blood Institute, National Institute of Diabetes and Digestive and Kidney Diseases. (1998). Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults: The evidence report.
18 Jensen MD, Ryan DH, Apovian CM, Ard JD, Comuzzie AG, Donato KA, et al. (2014). 2013 AHA/ACC/TOS guideline for the management of overweight and obesity in adults: A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines and the Obesity Society. Circulation.
19 HHS. (2010). The Surgeon General's vision for a healthy and fit nation.
20 Flegal KM, Graubard BI, Williamson DF, Gail MH. (2005). Excess deaths associated with underweight, overweight, and obesity. JAMA.
21 Andrae B, Andersson TM, Lambert PC, Kemetli L, Silfverdal L, Strander B, et al. (2012). Screening and cervical cancer cure: Population based cohort study. BMJ.
22 Agency for Healthcare Research and Quality, U.S. Preventive Services Task Force. (2014). Final recommendation statement: Cervical cancer: Screening, March 2012.
23 Institute of Medicine. (2006). Hospital-based emergency care: At the breaking point.
24 DeLia D, Cantor J. (2009). Emergency department utilization and capacity.
25 Taylor J. (2006). Don't bring me your tired, your poor: The crowded state of America's emergency departments.
26 Kaiser Commission on Medicaid and the Uninsured. (2012). The uninsured and the difference health insurance makes.
27 Cunningham PJ, Felland LE. (2008). Falling behind: Americans' access to medical care deteriorates, 2003–2007. Track Rep.
28 Blumenthal D, Tavenner M. (2010). The “meaningfuluse” regulationfor electronic health records. N Engl J Med.
29 Kern LM, Barrón Y, Dhopeshwarkar RV, Edwards A, Kaushal R, HITEC Investigators. (2013). Electronic health records and ambulatory quality of care. J Gen Intern Med.
30 Hsiao C-J, Hing E. (2014). Use and characteristics of electronic health record systems among office-based physician practices: United States, 2001–2013.
31 Decker SL. (2012). In 2011 nearly one-third of physicians said they would not accept new Medicaid patients, but rising fees may help. Health Aff (Millwood).
32 NCHS. National Electronic Health Records Survey 2013.
33 Hing E, Decker SL, Jamoom E. (2015). Acceptance of new patients with public and private insurance by office-based physicians: United States, 2013.
34 Ingram DD, Franco SJ. (2014). 2013 NCHS urban–rural classification scheme for counties. Vital Health Stat.
35 Martin AB, Hartman M, Benson J, Catlin A, National Health Expenditure Accounts Team. (2016). National health spending in 2014: Faster growth driven by coverage expansion and prescription drug spending. Health Aff (Millwood).
36 Martinez ME, Cohen RA. (2015). Health insurance coverage: Early release of estimates from the National Health Interview Survey, January–June 2015.
37 NCHS. (2015). National Health Interview Survey.
38 (2010). Patient Protection and Affordable Care Act. Stat.
39 Cohen RA, Martinez ME. (2015). Health insurance coverage: Early release of estimates from the National Health Interview Survey, 2014.
40 Kaiser Commission on Medicaid and the Uninsured. (2013). Medicaid eligibility for adults as of January 1, 2014.
41 Heckler MM. (1985). Report of the Secretary's Task Force on Black & Minority Health.
42 HHS. (2012). Offices of Minority Health National Partnership for Action to End Health Disparities.
43 Agency for Healthcare Research and Quality. National healthcare quality and disparity reports.
44 HHS. (2000). Healthy People 2010: Understanding and improving health.
45 HHS. HHS action plan to reduce racial and ethnic health disparities: A nation free of disparities in health and health care.
46 Cooper RS, Kaufman JS, Ward R. (2003). Race and genomics. N Engl J Med.
47 Williams DR, Sternthal M. (2010). Understanding racial-ethnic disparities in health: Sociological contribution. J Health Soc Behav.
48 Office of Management and Budget. (1977). Race and ethnic standards for federal statistics and administrative reporting. Statistical Policy Directive 15.
49 Office of Management and Budget. (1997). Revisions to the standards for the classification of federal data on race and ethnicity. Fed Regist.
50 U.S. Census Bureau, Population Division. (2015). Annual estimates of the resident population by sex, race, and Hispanic origin for the United States, states, and counties: April 1, 2010 to July 1, 2014.
51 DeNavas-Walt C, Proctor BD, U.S. Census Bureau. (2015). Income and poverty in the United States: 2014. Current Population Reports, P60–252.
52 U.S. Census Bureau. Current Population Survey (CPS): CPS table creator, 2014 data from the CPS' annual social and economic supplement.
53 Markides KS, Eschbach K. (2005). Aging, migration, and mortality: Current status of research on the Hispanic paradox. J Gerontol B Psychol Sci Soc Sci.
54 HHS. (2011). National partnership for action to end health disparities: Offices of minority health.
55 Keppel K, Pamuk E, Lynch J, et al. (2005). Methodological issues in measuring health disparities. NCHS. Vital Health Stat.
56 Keppel KG, Pearcy JN, Klein RJ. (2004). Measuring progress in Healthy People 2010. Healthy People Statistical Notes, no 25.
57 WHO. (2013). Handbook on health inequality monitoring with a special focus on low-and middle-income countries.
58 Harper S, Lynch J. (2005). Methods for measuring cancer disparities: A review using data relevant to Healthy People 2010 cancer-related objectives.
59 Talih M, Huang DT. (2016). Measuring progress toward target attainment and the elimination of health disparities in Healthy People 2020. Healthy People Statistical Notes, no 27.
60 Kochanek KD, Murphy SL, Xu JQ. (2015). Deaths: Final data for 2011. National vital statistics reports.
61 Kochanek KD, Arias E, Anderson RN. (2015). Leading causes of death contributing to decrease in life expectancy gap between black and white populations: United States, 1999–2013.
62 Singh GK, van Dyck PC. (2010). Infant mortality in the United States, 1935–2007: Over seven decades of progress and disparities.
63 Association of Maternal & Child Health Programs. (2010). Celebrating the legacy, shaping the future: 75 years of state and federal partnership to improve maternal and child health.
64 Chang HH, Larson J, Blencowe H, Spong CY, Howson CP, Cairns-Smith S, et al. (2013). Preventing preterm births: Analysis of trends and potential reductions with interventions in 39 countries with very high human development index. Lancet.
65 Ancel PY, Goffinet F, EPIPAGE-2 Writing Group. (2015). Survival and morbidity of preterm children born at 22 through 34 weeks' gestation in France in 2011: Results of the EPIPAGE-2 cohort study. JAMA Pediatr.
66 Adams JN, Feldman HM, Huffman LC, Loe IM. (2015). Sensory processing in preterm preschoolers and its association with executive function. Early Hum Dev.
67 Brown L, Burns YR, Watter P, Gibbons KS, Gray PH. (2015). Motor performance, postural stability and behaviour of non-disabled extremely preterm or extremely low birth weight children at four to five years of age. Early Hum Dev.
68 van der Pal-de Bruin KM, van der Pal SM, Verloove-Vanhorick SP, Walther FJ. (2015). Profiling the preterm or VLBW born adolescent; Implications of the Dutch POPS cohort follow-up studies. Early Hum Dev.
69 Stoll BJ, Hansen NI, Bell EF, Shankaran S, Laptook AR, Walsh MC, et al. (2010). Neonatal outcomes of extremely preterm infants from the NICHD Neonatal Research Network. Pediatrics.
70 Spong CY. (2013). Defining “term” pregnancy:Recommendationsfrom the Defining “Term” PregnancyWorkgroup. JAMA.
71 Mathews TJ, MacDorman MF, Thoma ME. (2015). Infant mortality statistics from the 2013 period linked birth/infant death data set. National vital statistics reports.
72 MacDorman MF, Mathews TJ. (2011). Understanding racial and ethnic disparities in US infant mortality rates.
73 Martin JA, Osterman MJK, Kirmeyer SE, Gregory ECW. (2015). Measuring gestational age in vital statistics data: Transitioning to the obstetric estimate. National vital statistics reports.
74 Hamilton BE, Martin JA, Osterman MJK, et al. (2015). Births: Final data for 2014. National vital statistics reports.
75 Osterman MJK, Martin JA. (2014). Trends in low-risk cesarean delivery in the United States, 1990–2013. National vital statistics reports.
76 D'Alton ME, Hehir MP. (2015). Cesarean delivery rates: Revisiting a 3-decades-old dogma. JAMA.
77 Carroll MD, Navaneelan T, Bryan S, Ogden CL. (2015). Prevalence of obesity among children and adolescents in Canada and the United States.
78 Organisation for Economic Co-operation and Development. (2014). Obesity update.
79 Ogden CL, Carroll MD, Fryar CD, Flegal KM. (2015). Prevalence of obesity among adults and youth: United States, 2011–2014.
80 National Heart Lung and Blood Institute. National High Blood Pressure Education Program.
81 Nwankwo T, Yoon SS, Burt V, Gu Q. (2013). Hypertension among adults in the United States: National Health and Nutrition Examination Survey, 2011–2012.
82 NCHS. National Health and Nutrition Examination Survey.
83 CDC. (2013). Racial/ethnic disparities in the awareness, treatment, and control of hypertension—United States, 2003–2010. MMWR.
84 Jamal A, Homa DM, O'Connor E, Babb SD, Caraballo RS, Singh T, et al. (2015). Current cigarette smoking among adults—United States, 2005–2014. MMWR.
85 HHS. (2014). The health consequences of smoking—50 years of progress: A Report of the Surgeon General, Chapter 12, 2014.
86 CDC. (2004). Experiences with obtaining influenza vaccination among persons in priority groups during a vaccine shortage—United States, October–November, 2004. MMWR.
87 Centers for Medicare & Medicaid Services. Children's Health Insurance Program (CHIP).
88 Kaiser Family Foundation. (2012). A guide to the Supreme Court's decision on the ACA's Medicaid expansion.
89 HHS. (2000). Oral health in America: A Report of the Surgeon General.
90 Bloom B, Cohen RA. (2010). Dental insurance for persons under age 65 years with private health insurance: United States, 2008.
91 Institute of Medicine and National Research Council. (2011). Improving access to oral health care for vulnerable and underserved populations.
92 National Association of Dental Plans. Who has dental benefits?.
93 Agency for Healthcare Research and Quality. Medical Expenditure Panel Survey household component tables. Table 3: Dental services—Median and mean expenses per person with expense and distribution of expenses by source of payment: United States, 2012.
94 SUDAAN. (2009). release 10.0.1 [computer software].
95 CDC. (2014). Youth Risk Behavior Surveillance System (YRBSS). Interpretation of YRBS trend data.