# Highlights

This section presents selected data from this year’s Special Feature on the health of the population aged 55–64 and from the four major areas included in the report: health status and determinants, utilization of health resources, health care resources, and health care expenditures and payers. The section focuses on topics of public health importance and illustrates the breadth of material included in Health, United States. Each highlight includes a reference to the detailed trend table, spreadsheet file, or figure where more information can be obtained.

## Special Feature on Adults Aged 55–64

All-cause death rates in 2013 for those aged 55–64 were 6% lower for men and 11% lower for women than in 2003, driven by decreases in death rates for cancer and heart disease (Figure 20).

In 2012–2013, 18.1% of noninstitutionalized adults aged 55–64 were current cigarette smokers, 8% lower than the percentage in 2002–2003 (19.7%) (Figure 23).

For adults aged 55–64, the percentage with private health insurance was lower for all family income groups in 2012– 2013 compared with 2002–2003, with the largest loss of private coverage occurring for those with family income below 200% of the poverty level (Figure 25).

In 2009–2012, the percentage of adults aged 55–64 who took no, 1–4, or 5 or more prescription drugs in the past 30 days was similar to levels in 1999–2002; use of prescription cholesterol-lowering drugs was 54% higher among 55- to 64-year-olds in 2009–2012 (31.8%) compared with 1999–2002 (20.6%) (Figure 28).

## Health Status and Determinants

### Life Expectancy and Mortality

In 2013, life expectancy at birth in the United States for the total population was 78.8 years—76.4 years for males and 81.2 years for females (Table 16).

Between 2003 and 2013, life expectancy at birth increased 1.9 years for males and 1.5 years for females. The gap in life expectancy between males and females narrowed from 5.2 years in 2003 to 4.8 years in 2013 (Table 16).

Between 2003 and 2013, life expectancy at birth increased more for the black than for the white population, thereby narrowing the gap in life expectancy between these two racial groups. In 2003, life expectancy at birth for the white population was 5.3 years longer than for the black population; by 2013, the difference had narrowed to 3.6 years (Table 16).

Between 2003 and 2013, the infant mortality rate decreased 13%, from 6.85 to 5.96 deaths per 1,000 live births. In 2003, the infant mortality rate for white mothers was 5.72, compared with 14.01 for black mothers; by 2013, the infant mortality rate declined to 5.07 among white mothers and 11.22 among black mothers (Table 12).

In 2013, the 10 leading causes of death were heart disease, cancer, chronic lower respiratory diseases, unintentional injuries, stroke, Alzheimer’s disease, diabetes, influenza and pneumonia, nephritis, and suicide. These 10 causes of death accounted for 74% of the 2.6 million deaths in 2013 (Table 20).

Between 2003 and 2013, the age-adjusted heart disease death rate decreased 28%, from 236.3 to 169.8 deaths per 100,000 population. In 2013, 24% of all deaths in the United States were from heart disease (Tables 20 and 24).

Between 2003 and 2013, the age-adjusted cancer death rate decreased 15%, from 190.9 to 163.2 deaths per 100,000 population. In 2013, 23% of all deaths in the United States were from cancer (Tables 20 and 26).

Between 2003 and 2013, the age-adjusted suicide death rate increased 17%, from 10.8 to 12.6 deaths per 100,000 population. In 2013, 17% of deaths among those aged 15–24 and 11% of deaths among those aged 25–44 were from suicide (Tables 21 and 33).

Between 2003 and 2013, the age-adjusted drug poisoning death rate involving opioid analgesics increased from 2.9 to 5.1 deaths per 100,000 population. In 2013, the drug poisoning death rate involving opioid analgesics was highest among those aged 45–54 (10.6), followed by those aged 35–44 (8.6), 25–34 (7.5), and 55–64 (7.5) (Table 30).

### Fertility and Natality

Between 2003 and 2013, the birth rate among teenagers aged 15–19 fell 36%, from 41.1 to 26.5 live births per 1,000 females—a record low for the United States (Table 3).

The percentage of low-birthweight births (infants weighing less than 2,500 grams [5.5 pounds] at birth) was 8.02% in 2013, down 3% from the recent high of 8.26% in 2006 (Table 6).

### Health Risk Factors

#### Children

In 2009–2012, the prevalence of obesity among children aged 2–5 years was 10.2%, 17.9% among children aged 6–11, and 19.4% among adolescents aged 12–19 (Table 65 and Figure 10).

In 2013, 16.3% of 12th graders, 9.1% of 10th graders, and 4.5% of 8th graders had smoked cigarettes in the past 30 days. Smoking prevalence declined for all grades from 2003 levels, when 24.4% of 12th graders, 16.7% of 10th graders, and 10.2% of 8th graders reported smoking cigarettes in the past 30 days (Table 56).

In 2013, 24.7% of students in grades 9–12 reported they were in a physical fight during the past year, and the percentage was higher among male students (30.2%) than female students (19.2%) (Table 57).

In 2013, 21.9% of students in grades 9–12 rode in a car in the past 30 days with a driver who had been drinking alcohol, down from 30.2% in 2003 (Table 57).

#### Adults

In 2013, 20.4% of adults aged 18 and over met the 2008 federal physical activity guidelines for both aerobic activity and muscle strengthening (Table 63).

Between 1988–1994 and 2009–2012, the percentage of adults aged 20 and over with grade 1 obesity (a body mass index [BMI] of 30.0–34.9) increased from 14.8% to 20.4%. Those with grade 2 obesity (BMI of 35.0–39.9) rose from 5.2% to 8.6%, and those with grade 3 or higher obesity (BMI of 40 or higher) doubled, from 3.0% to 6.3% (percentages are age-adjusted) (Table 64).

In 2013, 17.8% of noninstitutionalized adults aged 18 and over were current cigarette smokers, a decline from 2000 (23.2%). Men (20.5%) were more likely than women (15.3%) to be current cigarette smokers (Table 52).

### Measures of Health and Disease Prevalence

In 2011–2013, 5.3% of children under age 18 had an asthma attack in the past year, and 5.6% had a food allergy (Table 39).

Among children aged 5–17, 10.1% were diagnosed with attention deficit/hyperactivity disorder and 5.5% had serious emotional or behavioral difficulties in 2011–2013 (Table 39).

In 2013, the percentage of noninstitutionalized adults who reported their health as fair or poor ranged from 6.2% of those aged 18–44 to 27.6% of those aged 75 and over (Table 50).

In 2013, 58.9% of noninstitutionalized adults aged 65 and over reported having at least one basic actions difficulty (e.g., movement, emotional, sensory [seeing or hearing], or cognitive difficulty) and 32.0% of noninstitutionalized adults aged 65 and over reported having at least one complex activity limitation (e.g., self-care, social, or work limitation) (Table 47).

In 2012–2013, 12.1% of noninstitutionalized adults aged 45–64 and 29.8% of noninstitutionalized adults aged 65 and over had ever been told by a physician or other health professional that they had heart disease (Table 42).

In 2012–2013, 6.7% of noninstitutionalized adults aged 45–64 and 18.4% of noninstitutionalized adults aged 65 and over had ever been told by a physician or other health professional that they had cancer (excluding squamous and basal cell skin cancers) (Table 42).

The prevalence of diabetes increases with age. In 2009– 2012, 3.7% of adults aged 20–44, 16.2% of adults aged 45–64, and 26.8% of adults aged 65 and over had diabetes (physician-diagnosed and undiagnosed) (Table 44 and Figure 6).

In 2009–2012, nearly one-third (32.2%) of adults aged 20 and over had hypertension (diagnosed and undiagnosed). Of adults aged 20 and over with hypertension (diagnosed and undiagnosed), nearly one-half (47.4%) continued to have uncontrolled high blood pressure (Table 60 and Figure 9).

## Utilization of Health Resources

### Use of Health Care Services

In 2013, 15.8% of persons had no health care visits in the past year, 47.0% had 1–3 health care visits, 24.5% had 4–9 visits, and 12.7% had 10 or more visits. Health care visits for illness, preventive care, or an injury include visits to see a health care provider at physician offices, emergency departments, clinics, or some other place, and home visits by health care professionals (Table 71).

In 2011, there were 126 million visits to hospital outpatient departments and 136 million visits to hospital emergency departments (Table 82).

In 2013, 83.0% of children aged 2–17 years, 61.7% of adults aged 18–64, and 60.6% of adults aged 65 and over had visited a dentist in the past year (Table 84).

The percentage of the population taking at least one prescription drug during the past 30 days increased from 39.1% in 1988–1994 to 47.3% in 2009–2012. During the same period, the percentage taking three or more prescription drugs rose from 11.8% to 20.6%, and the percentage taking five or more drugs more than doubled, from 4.0% to 10.1% (percentages are age-adjusted) (Table 85).

### Use of Preventive Medical Care Services

In 2013, 70% of children aged 19–35 months had completed the combined series of childhood vaccinations (at least 4 doses of diphtheria/tetanus/pertussis vaccine, 3 doses of polio vaccine, 1 dose of measles-containing vaccine, 3 or 4 doses of Haemophilus influenzae type b vaccine depending on product type, 3 doses of hepatitis B vaccine, 1 dose of varicella vaccine, and 4 doses of pneumococcal conjugate vaccine) (Table 72 and Figure 13).

In 2013, 41.0% of noninstitutionalized adults aged 18 and over had received an influenza vaccination in the past year. Influenza vaccination increased with age, with 29.6% of those aged 18–49, 46.6% of those aged 50–64, and 67.9% of those aged 65 and over reporting an influenza vaccination in the past year (Table 74 and Figure 12).

In 2013, 59.7% of noninstitutionalized adults aged 65 and over ever had a pneumococcal vaccination (Table 75 and Figure 12).

In 2013, two-thirds of women aged 40 and over had a mammogram in the past 2 years. Between 2003 and 2013, mammography use decreased 7% among women aged 40–49 (to 59.6% in 2013), 6% among those 50–64 (to 71.4%), and 7% among those 75 and over (to 56.5%), while remaining steady among those aged 65–74 (75.3% in 2013). Recommendations regarding which age groups should have screening mammograms have changed over time (Table 76).

In 2013, almost 7 of 10 women aged 18 and over had a Pap smear in the past 3 years (69.4%). Those aged 65 and over were less likely to have had a recent Pap smear (42.7%) than those aged 18–44 (77.2%) and 45–64 (73.9%). Currently, the U.S. Preventive Services Task Force does not recommend Pap smear screening for women aged 65 and over at low risk for cervical cancer (Table 77).

In 2013, almost 6 of 10 adults aged 50–75 had the recommended colorectal cancer screening tests (57.8%). Those aged 50–75 with at least some college education were more likely to have been screened (63.1%) than those with only a high school diploma or GED (53.4%) or those without a high school diploma (43.5%). Currently, the U.S. Preventive Services Task Force recommends colorectal cancer screening for those aged 50–75 (Table 78).

### Nonreceipt of Needed Medical Care, Prescription Drugs, and Dental Care Due to Cost

In 2013, among noninstitutionalized persons, 9.1% reported not receiving or delaying needed medical care due to cost, 6.4% reported not receiving needed prescription drugs due to cost, and 11.1% reported not receiving needed dental care due to cost (Table 69).

Among adults aged 18–64, the percentage who reported not receiving or delaying seeking needed medical care due to cost in the past 12 months increased during 2003–2010, then was stable during 2010–2013. Among adults aged 18–64, the percentage who reported not receiving needed prescription drugs due to cost in the past 12 months increased during 2003–2010, then declined during 2010– 2013. Among adults aged 18–64, the percentage who reported not receiving needed dental care due to cost in the past 12 months increased during 2003–2010, then was stable through 2013 (Table 69).

## Health Care Resources

In 2012, there were 26.9 physicians in patient care per 10,000 population in the United States. The number of patient care physicians per 10,000 population ranged from 18.0 in Idaho and Mississippi to 41.3 in Massachusetts and 65.9 in the District of Columbia (Table 92).

In 2012, the United States had 4,999 community hospitals and 800,566 community hospital beds. Community hospital occupancy averaged 63.4% in 2012, similar to the levels in 2010 and 2011 (Table 98).

In 2013, there were 15,663 certified nursing homes with 1,697,484 nursing home beds. U.S. nursing home occupancy averaged 80.8% in 2013. Nursing home occupancy rates were highest in North Dakota (92.9%) and the District of Columbia (92.9%) in 2013 (Table 101).

## Health Care Expenditures and Payers

### Health Care Expenditures

In 2013, personal health care expenditures in the United States totaled $2.5 trillion, a 3.8% increase from 2012. The per capita personal health care expenditure for the total U.S. population was $7,826 in 2013, up from $7,597 in 2012 (Table 102).

Expenditures for hospital care accounted for 38.0% of all personal health care expenditures in 2013. Physician and clinical services accounted for 23.8% of total personal health care expenditures, prescription drugs for 11.0%, and nursing care facilities and continuing care retirement communities for 6.3%; the remainder of spending was for other types of care (Table 103).

In 2013, prescription drug expenditures totaled $271.1 billion, up from $264.4 billion in 2012 (Table 103).

In 2012, the average inflation-adjusted cost for the entire hospitalization involving a heart valve procedure was $52,625, a coronary artery bypass graft procedure was $40,142, cardiac pacemaker or defibrillator insertion or replacement was $35,028, and spinal fusion was $28,190 (Table 105).

### Health Care Payers

In 2013, 34.3% of all personal health care expenditures were paid by private health insurance, 22.3% were paid by Medicare, and 16.6% by Medicaid; consumers paid 13.7% out of pocket; and the remainder was paid by other types of insurance, payers, and programs (Table 104).

In 2011, children under age 21 accounted for 47.2% of Medicaid recipients but only 19.6% of Medicaid expenditures. The aged and blind and persons with disabilities accounted for 20.3% of Medicaid recipients and 60.6% of Medicaid expenditures (Table 118).

In 2013, the Medicare program had 52.3 million enrollees and expenditures of $582.9 billion, up from 50.9 million enrollees and $574.2 billion expenditures the previous year. Expenditures for the Medicare drug program (Part D) were $69.7 billion in 2013 (Table 116).

### Health Insurance Coverage

Between 2003 and 2013, the percentage of adults aged 18–64 who were uninsured increased 6% from 19.3% to 20.5% (Table 114).

Based on preliminary data, from 2013 to the second quarter of 2014 (April–June), the percentage of adults aged 18–64 who were uninsured declined 24%, to 15.6% (preliminary data; Martinez ME, Cohen RA. Health insurance coverage: Early release of estimates from the National Health Interview Survey, January–June 2014. NCHS; 2014. Available from: http://www.cdc.gov/nchs/data/nhis/earlyrelease/Quarterly_estimates_2010_2014_Q12.pdf).

Between 2003 and 2010, the percentage of adults aged 19–25 who were uninsured was stable at 31%–34%, and then decreased to 26.7% in 2013 (Table 114).

Based on preliminary data, from 2013 to the second quarter of 2014 (April–June), the percentage of adults aged 19–25 who were uninsured declined 28%, to 19.2% (preliminary data; Martinez ME, Cohen RA. Health insurance coverage: Early release of estimates from the National Health Interview Survey, January–June 2014. NCHS; 2014. Available from: http://www.cdc.gov/nchs/data/nhis/earlyrelease/insur201412.pdf and unpublished data).

Between 2003 and 2013, the percentage of the population under age 65 with private health insurance obtained through the workplace declined from 64.4% to 56.6% (Table 112).

Between 2003 and 2013, among children in families with income of 100%–199% of poverty, the percentage of uninsured children under age 18 dropped from 15.6% to 11.1%, while Medicaid or the Children’s Health Insurance Program (CHIP) coverage among children in families with income of 100%–199% of poverty increased from 41.7% to 60.1% (Tables 113 and 114).

In 2013, Massachusetts (4.4%), the District of Columbia (7.1%), Puerto Rico (7.7%), Vermont (8.1%), and Hawaii (8.3%) had the lowest percentages of persons uninsured (i.e., without public or private coverage) among those under 65, while Nevada (23.4%), Florida (24.2%), and Texas (24.5%) had the highest percentages (Table 123, a new table in the 2014 edition).