# Acknowledgments

Overall responsibility for planning and coordinating the content of this volume rested with the National Center for Health Statistics’(NCHS) Office of Analysis and Epidemiology, under the direction of Julia S. Holmes and Irma E. Arispe.

Production of Health, United States, 2014 was managed by Sheila J. Franco, Virginia M. Freid, and Julia S. Holmes. Preparation of the volume, including highlights, trend tables, appendixes, and index was completed by Mary Ann Bush, La-Tonya D. Curl, Anne K. Driscoll, Catherine R. Duran, Sheila J. Franco, Virginia M. Freid, Nancy Han, Hashini S. Khajuria, Ji-Eun Kim, Xianfen Li, Anita L. Powell, Ilene B. Rosen, and Naga Shanmugam. Administrative and word processing assistance was provided by Lillie C. Featherstone.

Production of the Chartbook was managed by Sheila J. Franco and Virginia M. Freid. The Special Feature on Adults Aged 55–64 was prepared and written by Virginia M. Freid with Ji-Eun Kim. Data and analysis for specific charts were provided by Sheila J. Franco, Virginia M. Freid, Hashini S. Khajuria, and Ji-Eun Kim. Technical assistance and programming were provided by Mary Ann Bush, La-Tonya D. Curl, Catherine R. Duran, Nancy Han, and Xianfen Li.

Publication production was performed by CDC/OSELS/NCHS/OD/Office of Information Services, Information Design and Publishing Staff (IDPS). Project management was provided by Elom L. Lawson and Barbara J. Wassell. Editorial review was provided by Jane Sudol, Barbara J. Wassell, and Danielle Woods. Graphic design was provided by Odell D. Eldridge (contractor) and Kyung M. Park. Layout and production were done by Jacqueline M. Davis and Zung T. Le. Overview for IDPS publications and electronic products was provided by Kimberly N. Ross and Tommy C. Seibert, Jr. Printing was managed by Nathanael Brown, CDC/OD/OADC.

Electronic access through the NCHS website was provided by Christine J. Brown, Jacqueline M. Davis, Virginia M. Freid, Hashini S. Khajuria, Ji-Eun Kim, Elom L. Lawson, Zung T. Le, Anthony Lipphardt, Jennifer A. Moore, Kyung M. Park, Anita L. Powell, Anthony R. Quintana, Ilene B. Rosen, and Barbara J. Wassell.

Data and technical assistance were provided by staff of the following NCHS organizations: Division of Health Care Statistics: Susan M. Schappert; Division of Health and Nutrition Examination Surveys: Naman Ahluwalia, Margaret D. Carroll, Mark S. Eberhardt, Qiuping Gu, Brian K. Kit, Cynthia L. Ogden, Ryne Paulose-Ram, and Sung Sug (Sarah) Yoon; Division of Health Interview Statistics: Patricia F. Adams, Veronica E. Benson, Lindsey Black, Debra Blackwell, Barbara Bloom, Tainya Clarke, Robin A. Cohen, Gulnur Freeman, Jacqueline Lucas, Michael Martinez, Colleen Nugent, Jeannine Schiller, Charlotte Schoenborn, Maria Villarroel, and Brian Ward; Division of Vital Statistics: Robert N. Anderson, Joyce A. Arbertha, Elizabeth Arias, Amy M. Branum, Melonie Heron, Jo Jones, Sharon E. Kirmeyer, Kenneth D. Kochanek, Annie Liu, Marian F. MacDorman, Joyce A. Martin, T. J. Mathews, Arialdi M. Miniño, Jaleh Mousavi, Sherry L. Murphy, Steven J. Steimel, Betzaida Tejada-Vera, and Elizabeth C. Wilson; Office of Analysis and Epidemiology: Li-Hui Chen, Catherine R. Duran, Deborah D. Ingram, Laura A. Pratt, Cheryl V. Rose, and Ritu Tuteja; Office of the Center Director: Juan Albertorio and Francis C. Notzon; and Office of Research and Methodology: Meena Khare.

Additional data and technical assistance were provided by the following organizations of the Centers for Disease Control and Prevention (CDC): National Center for Chronic Disease Prevention and Health Promotion: Karen Pazol; National Center for HIV/AIDS, Viral Hepatitis, STD, and TB Prevention: Lori Elmore, Anna Satcher Johnson, Laura Kann, Steve Kinchen, Jennifer A. Ludovic, and the Surveillance and Data Management Branch; Office of Public Health Scientific Services, Center for Surveillance, Epidemiology, and Laboratory Services: Ruth Ann Jajosky; National Institute for Occupational Safety and Health: Roger Rosa; by the following organizations within the Department of Health and Human Services: Agency for Healthcare Research and Quality: Roxanne Andrews, Anne Elixhauser, and Steven R. Machlin; Centers for Medicare & Medicaid Services: Catherine A. Curtis, Tony Dean, Maria Diacogiannis, Nathan Espinosa, Micah Hartman, Deborah W. Kidd, Barbara S. Klees, David Lassman, Anne Martin, Maggie S. Murgolo, Arun Natarajan, Joseph F. Regan, Jeffrey S. Silverman, Christopher J. Truffer, and Lekha Whittle; National Institutes of Health: Kathy Cronin, Bruce Dye, Paul Eggers, Lloyd Johnston, Marsha Lopez, the Monitoring the Future Team, and Anne-Michelle Noone; Substance Abuse and Mental Health Services Administration: Beth Han, Kevin Hennessey, Sharon Larson, Neil Russell, and Judith Teich; and by the following governmental and nongovernmental organizations: U.S. Census Bureau: Bernadette D. Proctor and Danielle Taylor; Bureau of Labor Statistics: Elizabeth Ashack, Christen Byler, and Audrey Watson; Department of Veterans Affairs: Tom Garin, Pheakdey Lim, and Dat Tran; American Association of Colleges of Pharmacy: Danielle A. Taylor and Jamie N. Taylor; American Association of Colleges of Osteopathic Medicine: Lisa M. Cole; American Association of Colleges of Podiatric Medicine: Moraith G. North; American Dental Education Association: Sylvia M. Zeno; American Medical Association Physician Masterfile: Cheryl Ashe; Association of American Medical Colleges: Brianna Gunter and Will Weiler; Association of Schools and Colleges of Optometry: Joanne Zuckerman; Association of Schools & Programs of Public Health: Christine M. Plepys; Cowles Research Group: C. McKeen Cowles; and NOVA Research Company: Shilpa Bengeri.