# Data Sources

Health, United States consolidates the most current data on the health of the population of the United States, the availability and use of health care resources, and health care expenditures. Information was obtained from the data files and published reports of many federal government, private, and global agencies and organizations. In each case, the sponsoring agency or organization collected data using its own methods and procedures. Therefore, data in this report may vary considerably with respect to source, method of collection, definitions, and reference period.

Although a detailed description and comprehensive evaluation of each data source are beyond the scope of this appendix, readers should be aware of the general strengths and weaknesses of the different data collection systems shown in Health, United States. For example, population-based surveys are able to collect socioeconomic data and information on the impact of an illness, such as limitation of activity. These data are limited by the amount of information a respondent remembers or is willing to report. For example, a respondent may not know detailed medical information, such as a precise diagnosis or the type of medical procedure performed, and therefore cannot report that information. In contrast, records-based surveys, which collect data from physician and hospital records, usually contain good diagnostic information but little or no information about the socioeconomic characteristics of individuals or the impact of illnesses on individuals.

Different data collection systems may cover different populations, and understanding these differences is critical to interpreting the resulting data. Data on vital statistics and national expenditures cover the entire population. However, most data on morbidity cover only the civilian noninstitutionalized population and thus may not include data for military personnel, who are usually young; for institutionalized people, including the prison population, who may be of any age; or for nursing home residents, who are usually older.

All data collection systems are subject to error, and records may be incomplete or contain inaccurate information. Respondents may not remember essential information, a question may not mean the same thing to different respondents, and some institutions or individuals may not respond at all. It is not always possible to measure the magnitude of these errors or their effect on the data. Where possible, table notes describe the universe and method of data collection, to assist users in evaluating data quality.

Some information is collected in more than one survey, and estimates of the same statistic may vary among surveys because of different survey methodologies, sampling frames, questionnaires, definitions, and tabulation categories. For example, cigarette use is measured by the National Health Interview Survey, the National Survey on Drug Use & Health, the Monitoring the Future Study, and the Youth Risk Behavior Survey. These surveys use slightly different questions, cover persons of differing ages, and interview in diverse settings (e.g., at school compared with at home), so estimates may differ.

Overall estimates generally have relatively small sampling errors, but estimates for certain population subgroups may be based on a small sample size and have relatively large sampling errors. Numbers of births and deaths from the National Vital Statistics System represent complete counts (except for births in those states where data are based on a 50% sample for certain years). Therefore, these data are not subject to sampling error. However, when the figures are used for analytical purposes, such as the comparison of rates over a period, the number of events that actually occurred may be considered as one of a large series of possible results that could have arisen under the same circumstances. When the number of events is small and the probability of such an event is rare, estimates may be unstable, and considerable caution must be used in interpreting the statistics. Estimates that are unreliable because of large sampling errors or small numbers of events are noted with asterisks in tables, and the criteria used to determine unreliable estimates are indicated in an accompanying footnote.

In this appendix, government data sources are listed alphabetically by data set name, and private and global sources are listed separately. To the extent possible, government data systems are described using a standard format. The Overview is a brief, general statement about the purpose or objectives of the data system. The Coverage section describes the population or events that the data system covers: for example, residents of the United States, the noninstitutionalized population, persons in specific population groups, or other entities that are included in the survey or data system. The Methodology section presents a short description of the methods used to collect the data. The Sample Size and Response Rate section provides these statistics for surveys. The Issues Affecting Interpretation section describes major changes in the data collection methodology or other factors that must be considered when analyzing trends shown in Health, United States: for example, a major survey redesign that may introduce a discontinuity in the trend. For additional information about the methodology, data files, and history of a data source, consult the References and For More Information sections that follow each summary.

## Government Sources

### Abortion Surveillance System

#### CDC/National Center for Chronic Disease Prevention and Health Promotion (NCCDPHP)

##### Overview

The Abortion Surveillance System documents the number and characteristics of women obtaining legal induced abortions in the United States.

##### Coverage

The system includes women of all ages, including adolescents, who obtain legal induced abortions.

##### Methodology

Each year, CDC requests tabulated data from the central health agencies of 52 reporting areas (the 50 states, the District of Columbia [D.C.], and New York City) to document the number and characteristics of women obtaining abortions in the United States. For the purpose of surveillance, a legal induced abortion is defined as an intervention performed by a licensed clinician (e.g., a physician, nurse-midwife, nurse practitioner, or physician assistant) that is intended to terminate a suspected or known ongoing intrauterine pregnancy and produce a nonviable fetus at any gestational age.

In most states, collection of abortion data is facilitated by the legal requirement for hospitals, facilities, and physicians to report abortions to a central health agency. These central health agencies voluntarily report abortion data to CDC and provide only the aggregate numbers for the abortion data they have collected through their independent surveillance systems. Although reporting to CDC is voluntary, most reporting areas provide aggregate abortion numbers; during 2002–2011, a total of 46 reporting areas provided CDC a continuous annual record of abortion numbers.

##### Issues Affecting Interpretation

Because reporting areas establish their own reporting requirements for abortion and send their data to CDC voluntarily, CDC is unable to obtain the total number of abortions performed in the United States. Although most states legally require medical providers to submit a report for all the abortions they perform, enforcement of this requirement varies. Additionally, although most reporting areas collect and send abortion data to CDC, during 2002–2011, 6 of the 52 reporting areas did not provide CDC with data on a consistent annual basis (the six states that did not report continuously for the period 2002–2011 were: Alaska, California, Louisiana, Maryland, New Hampshire, and West Virginia). Because of these limitations, during the period covered by this report, the total annual number of abortions recorded by CDC was consistently approximately 70% of the number recorded by the Guttmacher Institute, which uses numerous active follow-up techniques to increase the completeness of the data obtained through its periodic national census of abortion providers.

###### Reference

Pazol K, Creanga AA, Burley KD, Jamieson DJ. Abortion surveillance—United States, 2011. MMWR Surveill Summ. 2014;63(SS–11):1-41. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/ss6311a1.htm?s_cid=ss6311a1_e#Tab1.

##### For More Information

See the NCCDPHP surveillance and research website at: http://www.cdc.gov/reproductivehealth/Data_Stats/index.htm.

### American Community Survey (ACS)

#### U.S. Census Bureau

##### Overview

ACS provides annual estimates of income, education, employment, health insurance coverage, and housing costs and conditions for U.S. residents. Estimates from ACS complement data on population counts collected by the U.S. Census Bureau during the decennial census. Topics currently included on an annual basis in ACS were previously collected once a decade through the decennial census long form.

##### Coverage

ACS covers U.S. residents residing in all 3,141 counties in the 50 states and the District of Columbia, and all 78 municipalities in Puerto Rico. ACS began data collection for U.S. residents residing in housing units in January 2005 and for residents residing in group quarters facilities in January 2006. Annual ACS estimates are available every year for states and for specific geographic areas with populations of 65,000 or more.

##### Methodology

Starting with 2013 data, the ACS data collection operation uses up to four modes to collect information: Internet, mail, telephone, and personal visit interviews. The first mode includes a mailed request to respond to the ACS questionnaire over the Internet, followed later by an option to complete a paper questionnaire and return it by mail. If neither an Internet nor mail questionnaire is received, a follow-up interview by phone or personal visit is attempted for a sample of nonrespondents. Prior to 2013, Internet collection was not used, and only three modes of collection were used. Each month, a sample of housing unit addresses and residents of group quarters facilities receive questionnaires. Housing units include a house, apartment, mobile home or trailer, a group of rooms, or a single room occupied as separate living quarters, or if vacant, intended for occupancy as separate living quarters. Group quarters are places where people live or stay that are normally owned or managed by an entity or organization providing housing and services for the residents. These services may include custodial or medical care as well as other types of assistance, and residency is commonly restricted to persons receiving these services. The group quarters population comprises both the institutional and noninstitutional group quarters populations. The institutional group quarters population includes residents under formally authorized supervised care, such as those in skilled nursing facilities, adult correctional facilities, and psychiatric hospitals. The noninstitutional group quarters population includes residents of colleges or university housing, military barracks, and group homes.

ACS creates two sets of weights: a weight to each sample person record (both household and group quarters persons) and a weight to each sample housing unit record. For information on the weighting procedure, see the ACS methodology website at: http://www.census.gov/acs/www/methodology/methodology_main/.

##### Sample Size and Response Rate

Each year from 2005 through 2010, approximately 2.9 million housing unit addresses in the U.S. and 36,000 in Puerto Rico were selected to participate in ACS. Starting in 2011, the housing unit sample was increased to 3.54 million addresses per year. For 2005–2012, the housing unit response rate was 97%–98%; in 2013, the housing unit response rate was 90%. Beginning in 2006, the ACS sample was expanded to include 2.5% of the population living in group quarters, which included approximately 20,000 group quarters facilities and 195,000 residents of group quarters in the United States and Puerto Rico. In 2013, the group quarters sample for college dorms was restricted to the nonsummer months. The group quarters response rate ranged between 95% and 98% for 2005–2013. For year-specific response rates, see: http://www.census.gov/acs/www/methodology/response_rates_data/.

##### Issues Affecting Interpretation

Several changes were made to the ACS questionnaire at the beginning of 2008, including the introduction of new questions on health insurance coverage. Health insurance coverage estimates are methodologically consistent for data year 2009 and subsequent years (O’Hara). In addition, the methodology for weighting the group quarters survey changed starting in 2011.

###### References

Torrieri N. Program Staff. American Community Survey design and methodology (January 2014). Washington, DC. U.S. Census Bureau. 2014. Available from: http://www.census.gov/acs/www/Downloads/survey_methodology/acs_design_methodology_report_2014.pdf.
O’Hara B, Medalia C. CPS and ACS health insurance estimates: Consistent trends from 2009–2012. SEHSD working paper 2014–29. Washington, DC. U.S. CensusBureau, Social, Economic, and Housing Statistics Division. 2014. Available from: http://www.census.gov/hhes/www/hlthins/data/incpovhlth/2013/CPS_ACS_Trends.pdf.

##### For More Information

See the ACS website at: http://www.census.gov/acs/www/.

### Census of Fatal Occupational Injuries (CFOI)

#### Bureau of Labor Statistics (BLS)

##### Overview

CFOI compiles comprehensive and timely information on fatal work injuries to monitor workplace safety and to inform private and public health efforts to improve workplace safety.

##### Coverage

The data cover all 50 states and D.C. In selected years, data are available for Puerto Rico, the Virgin Islands, and Guam but are not included in Health, United States because of data comparability issues.

##### Methodology

CFOI is administered by BLS, in conjunction with participating state agencies, to compile counts that are as complete as possible to identify, verify, and profile fatal work injuries. Key information about each workplace fatal injury (occupation and other worker characteristics, equipment or machinery involved, and circumstances of the event) is obtained by cross-referencing source documents. For a fatal occupational injury to be included in the census, the decedent must have been employed (i.e., self-employed, working for pay, or volunteering) at the time of the event, engaged in a legal work activity, or present at the site of the incident as a requirement of his or her job. These criteria are generally broader than those used by federal and state agencies administering specific laws and regulations. Fatal work injuries that occur during a person’s commute to or from work are excluded from the census counts. Fatal work injuries to volunteer workers who are exposed to the same work hazards and perform the same duties or functions as paid employees and who meet the CFOI work relationship criteria are included.

Data for CFOI are compiled from various federal, state, and local administrative sources, including death certificates, workers’ compensation reports and claims, reports to various regulatory agencies, medical examiner reports, police reports, and news reports. Diverse sources are used because studies have shown that no single source captures all job-related fatal injuries. Source documents are matched so that each fatal work injury is counted only once. To ensure that a fatal work injury occurred while the decedent was at work, information is verified from two or more independent source documents or from a source document and a follow-up questionnaire.

##### Issues Affecting Interpretation

The numbers of fatal occupational injuries are revised once after the initial preliminary release. States have up to 8 months to update their initial published counts and may identify additional fatal work injuries after data collection has closed for a reference year. Fatal work injuries initially excluded from the published count because of insufficient information to determine work relationship may subsequently be verified as work-related and included in the revised counts. Increases in the published counts over the last 5 years based on additional information have averaged 165 fatal occupational injuries per year, or less than 4% of the annual total.

Beginning with 2003 data, CFOI began using the 2002 North American Industry Classification System (NAICS). Starting with 2009 data, CFOI began using the 2007 NAICS to classify industries. In Health, United States, industry data are presented at the two-digit level. Most of the differences between the 2002 and 2007 NAICS are at a more detailed level. Therefore, the adoption of the 2007 NAICS for CFOI is unlikely to affect the trend presented in Health, United States. (See Appendix II, Industry of employment.)

###### Reference

Bureau of Labor Statistics. Revisions to the 2012 Census of Fatal Occupational Injuries (CFOI) counts. Washington, DC. U.S. Department of Labor. 2014. Available from: http://www.bls.gov/iif/oshwc/cfoi/cfoi_revised12.pdf.

##### For More Information

See the CFOI website at: http://www.bls.gov/iif/oshcfoi1.htm and the CFOI section of the BLS Handbook of Methods at: http://www.bls.gov/opub/hom/pdf/homch9.pdf.

### Current Population Survey (CPS)

#### Bureau of Labor Statistics (BLS) and U.S. Census Bureau

##### Overview

CPS provides current estimates and trends in employment, unemployment, poverty, and other characteristics of the general labor force, the population as a whole, and various population subgroups.

##### Coverage

The Census 2000-based basic CPS sample was introduced in April 2004, and implementation was completed by July 2005 with coverage in every state and D.C. For CPS labor force data, the adult universe (i.e., the population of marriageable age) is composed of persons aged 15 and over in the civilian noninstitutionalized population. The sample for the March CPS supplement was expanded to include members of the Armed Forces who are living in a household with at least one civilian adult, as well as additional Hispanic households that are not included in the monthly labor force estimates.

##### Methodology

The CPS interview is divided into three basic parts: (a) household and demographic information, (b) labor force information, and (c) supplement information for months that include supplements. Comprehensive work experience information is gathered on the employment status, occupation, and industry of persons interviewed.

Estimates of poverty presented in Health, United States from CPS are derived from the Annual Social and Economic Supplement (ASEC), formerly called the Annual Demographic Supplement (ADS) and commonly called the March Supplement. ASEC collects data on family characteristics, household composition, marital status, migration, income from all sources, weeks worked, time spent looking for work or on layoff from a job, occupation and industry classification of the job held for the longest during the year, and receipt of noncash benefits (such as food stamps, school lunch program, employer-provided group health insurance plan, personal health insurance, Medicaid, Medicare, Tricare or military health care, and energy assistance).

The basic CPS sample is selected from multiple frames using multiple stages of selection. Each unit is selected with a known probability to represent similar units in the universe. The sample design is state-based, with the sample in each state being independent of the others. One person generally responds for all eligible members of a household.

The additional Hispanic sample is from the previous November’s basic CPS sample. If a person is identified as being of Hispanic origin from the November interview and is still residing at the same address in March, that housing unit is eligible for the March survey. This amounts to a near-doubling of the Hispanic sample because there is no overlap of housing units between the basic CPS samples in November and March.

The final CPS sample weight is the product of the basic weight, the adjustments for special weighting, the noninterview adjustment, the first-stage ratio adjustment factor, and the second-stage ratio adjustment factor. This final weight should be used when producing estimates from the basic CPS data. Differences in the questionnaire, sample, and data uses for the March CPS supplement result in the need for additional adjustment procedures to produce what is called the March Supplement weight.

##### Sample Size and Response Rate

Beginning with 2001, the Children’s Health Insurance Program (CHIP) sample expansion was introduced. This included an increase in the basic CPS sample to 60,000 households per month. Prior to 2001, estimates were based on 50,000 households per month. The expansion also included an additional 12,000 households that were allocated differentially across states, based on prior information of the number of uninsured children in each state, to produce statistically reliable current state data on the number of low-income children who do not have health insurance coverage. In an average month, the nonresponse rate for the basic CPS is about 7%–8%.

##### Issues Affecting Interpretation

Over the years, the number of income questions has expanded, questions on work experience and other characteristics have been added, and the month of interview was moved to March. In 2002, an ASEC sample increase was implemented, requiring more time for data collection. Thus, additional ASEC interviews are now taking place in February and April. However, even with this sample increase, most of the data collection still occurs in March.

In 1994, major changes were introduced that included a complete redesign of the questionnaire and the introduction of computer-assisted interviewing for the entire survey. In addition, some of the labor force concepts and definitions were revised. Prior to the redesign, CPS data were primarily collected using a paper-and-pencil form. Beginning in 1994, population controls were based on the 1990 census and adjusted for the estimated population undercount. Starting with Health, United States, 2003, poverty estimates for data years 2000 and beyond were recalculated based on the expanded CHIP sample, and Census 2000-based population controls were implemented. Starting with 2002 data, race-specific estimates are tabulated according to the 1997 Revisions to the Standards for the Classification of Federal Data on Race and Ethnicity and are not strictly comparable with estimates for earlier years. Starting with Health, United States, 2012, Census 2010-based population controls were implemented for poverty estimates for 2010 and beyond. For a discussion of the impact of the implementation of the Census 2010-based controls on poverty estimate trends, see: DeNavas-Walt, Proctor, and Smith (2012).

For 2013 data, the CPS ASEC used a split panel to test a new set of income questions. Data for 2013 presented in this report are consistent with 2012 and do not include the redesigned income questions.

###### References

U.S. Census Bureau. Current Population Survey: Design and methodology. Technical paper no 66. Washington, DC. U.S. Census Bureau. 2006. Available from: http://www.census.gov/prod/2006pubs/tp-66.pdf.
DeNavas-Walt C, Proctor BD, Smith JC. Income, poverty, and health insurance coverage in the United States: 2012. Current Population Reports, P–60–245. Washington, DC. U.S. Government Printing Office. 2013. Available from: http://www.census.gov/prod/2013pubs/p60-245.pdf.
DeNavas-Walt C, Proctor BD. Income and poverty in the United States: 2013. Current Population Reports, P–60–249. Washington, DC. U.S. Government Printing Office. 2014. Available from: http://www.census.gov/content/dam/Census/library/publications/2014/demo/p60-249.pdf.

##### For More Information

See the CPS website at: http://www.census.gov/cps.

### Department of Veterans Affairs National Enrollment and Patient Databases

#### Department of Veterans Affairs (VA)

##### Overview

The VA compiles and analyzes multiple data sets on the health and health care of its clients and other veterans to monitor access and quality of care and to conduct program and policy evaluations. The VA maintains nationwide systems that contain a statistical record for each episode of care provided under VA auspices, in VA and non-VA hospitals, nursing homes, VA residential rehabilitation treatment programs (formerly called domiciliaries), and VA outpatient clinics. The VA also maintains enrollment information for each veteran enrolled in the VA health care system.

##### Coverage

U.S. veterans who receive services within the VA medical system are included. Data are available for some nonveterans who receive care at VA facilities.

##### Methodology

Encounter data from VA clinical information systems are collected locally at each VA medical center and transmitted electronically to the VA’s Austin Automation Center for use in providing nationwide statistics, reports, and comparisons.

##### Issues Affecting Interpretation

The databases include users of the VA health care system. VA eligibility is a hierarchy based on service-connected disabilities, income, age, and availability of services. Therefore, different VA programs may serve populations with different sociodemographic characteristics than those served by other health care systems.

##### For More Information

See the VA Information Resource Center website at: http://www.virec.research.va.gov/Index.asp.

### Employee Benefits Survey—See Appendix I, National Compensation Survey (NCS)

### Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample

#### Agency for Healthcare Research and Quality (AHRQ)

##### Overview

HCUP is a family of health care databases and related software tools developed through a federal-state-industry partnership to build a multistate health data system for health care research and decision making. The National (Nationwide) Inpatient Sample (HCUP–NIS), a component of HCUP, is the largest all-payer inpatient care database that is publicly available in the United States.

HCUP–NIS contains a core set of clinical and nonclinical information found in a typical discharge abstract, including all-listed diagnoses and procedures, discharge status, patient demographics, and charges for all patients regardless of payer (e.g., persons covered by Medicare, Medicaid, and private insurance, as well as those without insurance coverage).

##### Coverage

HCUP–NIS for 2012 covers community hospital discharges (excluding discharges from rehabilitation or long-term acute hospitals) from 44 states, which contain about 94% of all U.S. community hospital discharges. Community hospitals are defined by the American Hospital Association as nonfederal, short-term, general, and other specialty hospitals, excluding hospital units of institutions.

The number of states participating in HCUP–NIS has generally increased each year. In the years of data presented, the number of states grew from 28 in 2000 to 37 in 2005, 45 in 2010, 46 in 2011, and 44 in 2012. In 2012, all states except Alabama, Delaware, Idaho, Maine, Mississippi, and New Hampshire were included. D.C. is not included.

##### Methodology

HCUP–NIS prior to 2012 was designed to approximate a 20% stratified sample of U.S. community hospitals (excluding rehabilitation hospitals). This universe of U.S. community hospitals was divided into strata using five hospital characteristics: ownership and control, bed size, teaching status, urban or rural location, and U.S. region. The pre-2012 HCUP–NIS was a stratified probability sample of hospitals in the frame, with sampling probabilities proportional to the number of U.S. community hospitals in each stratum. The frame was limited by the availability of inpatient data from the data sources participating in HCUP. Discharge records for all patients in the sampled hospitals were included in the pre-2012 HCUP–NIS.

In 2012, HCUP–NIS was redesigned to improve national estimates. To highlight the design change, beginning with 2012 data, AHRQ renamed HCUP–NIS from the “Nationwide Inpatient Sample” to the “National Inpatient Sample.” The redesigned HCUP–NIS is now a sample of discharge records from all HCUP-participating hospitals, rather than a sample of hospitals from which all discharges were retained. It approximates a 20% stratified sample of discharges from U.S. community hospitals, excluding rehabilitation and long-term acute care hospitals. For this report, the statistics for years prior to 2012 were regenerated using new trend weights taking into account the redesign, to permit longitudinal analysis.

The information abstracted from hospital discharge records is translated into a uniform format to facilitate both multistate and national-state comparisons and analyses.

Hospital costs are derived from total hospital charges using hospital-specific cost-to-charge ratios based on hospital cost reports from the Centers for Medicare & Medicaid Services. Hospital charges reflect the amount the hospital billed for the entire hospital stay and do not include professional (physician) fees. Costs will tend to reflect the actual costs to produce hospital services, whereas charges represent what the hospital billed for the care. Costs are adjusted for economy-wide inflation by removing increases that reflect the effect of changing average prices for the same goods and services. The U.S. Bureau of Economic Analysis Gross Domestic Product Price Index is used to remove economy-wide inflation. Additional inflation that is specific to the hospital sector is not removed in this calculation.

##### Sample Size and Response Rate

The 2012 HCUP–NIS contains data from 7.3 million hospital stays sampled from 4,378 hospitals.

##### Issues Affecting Interpretation

Weights are produced to create national estimates, but because the number of participating states has increased over time, estimates from earlier years may be biased if omitted states have substantially different hospitalization patterns than states that provided data.

###### Reference

Agency for Healthcare Research and Quality. Introduction to the HCUP National Inpatient Sample (NIS), 2012. Healthcare Cost and Utilization Project—HCUP: A federal-state-industry partnership in health data. Rockville, MD. AHRQ. 2014. Available from: http://www.hcup-us.ahrq.gov/db/nation/nis/NISIntroduction2012.pdf.

##### For More Information

See the HCUP website at: http://www.hcup-us.ahrq.gov/.

### Medicaid Statistical Information System (MSIS)

#### Centers for Medicare & Medicaid Services (CMS)

##### Overview

CMS works with its state partners to collect data on each person served by the Medicaid program, in order to monitor and evaluate access to and quality of care, trends in program eligibility, characteristics of enrollees, changes in payment policy, and other program-related issues. MSIS is the primary data source for Medicaid statistical information. Data collected include claims for services and their associated payments for each Medicaid beneficiary, by type of service. MSIS also collects information on the characteristics of every Medicaid-eligible individual, including eligibility and demographic information.

##### Coverage

Medicaid data for all 50 states and D.C. are available starting in 1999. The data include information about all individuals enrolled in the Medicaid program, the services they receive, and the payments made for those services.

##### Methodology

Beginning in FY 1999, as a result of legislation enacted from the Balanced Budget Act of 1997, states were required to submit individual eligibility and claims data tapes to CMS quarterly, through MSIS. Prior to FY 1999, states were required to submit an annual HCFA–2082 report, designed to collect aggregated statistical data on eligibles, recipients, services, and expenditures during a federal fiscal year (October 1 through September 30) or, at state option, to submit eligibility data and claims through MSIS. The claims data reflect bills adjudicated or processed during the year, rather than services used during the year.

Another source of Medicaid information, not used in Health, United States, is the Form CMS–64, Quarterly Expense Report, a product of the financial budget and grant system. The report is a statement of expenditures for the Medicaid program that the states submit to CMS 30 days after each quarter. The report is an accounting statement of actual expenditures made by the states for which they are entitled to receive federal reimbursement under Title XIX for that quarter. The amount claimed on form CMS–64 is a summary of expenditures derived from source documents such as invoices, cost reports, and eligibility records. For more information, see: http://medicaid.gov/Medicaid-CHIP-Program-Information/By-Topics/Data-and-Systems/MBES/CMS-64-Quarterly-Expense-Report.html.

Form CMS–64 shows the disposition of Medicaid grant funds for the quarter being reported and for previous years, the recoupments made or refunds received, and income earned on grant funds. The data on form CMS–64 are used to reconcile the monetary advance made on the basis of states’ funding estimates filed prior to the beginning of the quarter on form CMS–37, Medicaid Program Budget Report. As such, form CMS–64 is the primary source for making adjustments for any identified overpayments and underpayments to the states. Also incorporated into this process are disallowance actions forwarded from other federal financial adjustments. Finally, form CMS–64 provides information that forms the basis for a series of Medicaid financial reports and budget analyses. Also included are third-party liability (TPL) collections tables. TPL refers to the legal obligation of certain health care sources to pay the medical claims of Medicaid recipients before Medicaid pays these claims. Medicaid pays only after the TPL sources have met their legal obligation to pay.

##### Issues Affecting Interpretation

The Medicaid tables in Health, United States are based on MSIS data. Users of Medicaid data may note apparent inconsistencies in the data that are primarily due to the difference in information captured in MSIS compared with form CMS–64 reports. The most substantive difference is due to payments made to disproportionate share hospitals. Payments to disproportionate share hospitals do not appear in MSIS because states reimburse these hospitals directly and there is no fee-for-service billing. Other, less significant, differences between MSIS and form CMS–64 occur because adjudicated claims data are used in MSIS compared with actual payments reflected in form CMS–64. Differences also may occur because of internal state practices for capturing and reporting these data through two separate systems. Finally, national totals for form CMS–64 are different because they include other jurisdictions, such as the Northern Mariana Islands and American Samoa. Starting with 1999 data, MSIS excluded data from Puerto Rico and the U.S. Virgin Islands, which accounted for approximately 1 million eligibles and $250 million in Medicaid payments.

##### For More Information

See the CMS websites at: http://www.cms.hhs.gov/home/medicaid.asp and http://www.medicaid.gov/Medicaid-CHIP-Program-Information/By-Topics/Data-and-Systems/Data-and-Systems.html and the Research Data Assistance Center (ResDAC) website at: http://cms.gov/Research-Statistics-Data-and-Systems/Research/ResearchGenInfo/ResearchDataAssistanceCenter.html. (Also see Appendix II, Medicaid.)

### Medical Expenditure Panel Survey (MEPS)

#### Agency for Healthcare Research and Quality (AHRQ)

##### Overview

MEPS produces nationally representative estimates of health care use, expenditures, sources of payment, insurance coverage, and quality of care. MEPS consists of three components: the Household Component (HC), the Medical Provider Component (MPC), and the Insurance Component (IC). Data from MEPS–HC and MEPS–MPC are used in Health, United States.

##### Coverage

The U.S. civilian noninstitutionalized population is the primary population represented.

##### Methodology

MEPS–PC is a national probability survey conducted on an annual basis since 1996. The panel design of the survey features five rounds of interviewing covering two full calendar years. The HC is a nationally representative survey of the civilian noninstitutionalized population drawn from a subsample of households that participated in the prior year’s National Health Interview Survey. Missing expenditure data in the HC are imputed largely from data collected in the MPC.

The MPC collects data from hospitals, physicians, home health care providers, and pharmacies that were reported in the HC as providing care to MEPS sample persons. Data are collected in the MPC to improve the accuracy of the expenditure estimates that would be obtained if derived solely from the HC. The MPC is particularly useful in obtaining expenditure information for persons enrolled in managed care plans and Medicaid recipients. Sample sizes for the MPC vary from year to year depending on the HC sample size and the MPC sampling rates for providers.

The MEPS predecessor, the 1987 National Medical Expenditure Survey (NMES), consisted of two components: the Household Survey (HS) and the Medical Provider Survey (MPS). The NMES–HS component was designed to provide nationally representative estimates for the U.S. civilian noninstitutionalized population for the calendar year 1987. Data from the NMES–MPS component were used in conjunction with HS data to produce estimates of health care expenditures. The NMES–HS consisted of four rounds of household interviews. Income information was collected in a special supplement administered early in 1988. Events under the scope of the NMES–MPS included medical services provided by or under the direction of a physician, all hospital events, and home health care.

##### Sample Size and Response Rate

In 2011, the MEPS annual survey consisted of 13,449 families and 33,622 individuals. The annual response rate, which reflects nonresponse to the National Health Interview Survey from which the MEPS sample is selected, as well as nonresponse and attrition in MEPS, has averaged about 55% in recent years.

##### Issues Affecting Interpretation

The 1987 estimates are based on NMES, and 1996 and later years’ estimates are based on MEPS. Because expenditures in NMES were based primarily on charges, whereas those for MEPS were based on payments, data for NMES were adjusted to be more comparable with MEPS by using estimated charge-to-payment ratios for 1987. For a detailed explanation of this adjustment, see Zuvekas and Cohen (2002).

###### References

Ezzati-Rice TM, Rohde F, Greenblatt J. Sample design of the Medical Expenditure Panel Survey Household Component, 1998–2007. Methodology report no 22. Rockville, MD. Agency for Healthcare Research and Quality. 2008. Available from: http://www.meps.ahrq.gov/mepsweb/data_files/publications/mr22/mr22.shtml.
Zuvekas SH, Cohen JW. A guide to comparing health care expenditures in the 1996 MEPS to the 1987 NMES. Inquiry. 2002;39(1):76-86. [pmid: 12067078].

##### For More Information

See the MEPS website at: http://www.meps.ahrq.gov/mepsweb/.

### Medicare Administrative Data

#### Centers for Medicare & Medicaid Services (CMS)

##### Overview

CMS collects and synthesizes Medicare enrollment, spending, and claims data to monitor and evaluate access to and quality of care, trends in utilization, changes in payment policy, and other program-related issues. Data include claims information for services furnished to Medicare fee-for-service beneficiaries and Medicare enrollment data. Claims data include type of service, procedures, diagnoses, dates of service, charge amounts, and payment amounts. Enrollment data include date of birth, sex, race, ethnicity, and reason for entitlement.

##### Coverage

Enrollment data are for all persons enrolled in the Medicare program. Claims data include data for Medicare fee-for-service beneficiaries who received services and for whom claims were filed.

##### Methodology

The claims and utilization data files contain extensive utilization information at various levels of summarization for a variety of providers and services. There are many types and levels of these files: National Claims History (NCH) files, Standard Analytic files (SAFs), Medicare Provider and Analysis Review (MedPAR) files, Medicare enrollment files, and various other files.

The NCH 100% Nearline file contains all institutional and noninstitutional claims and provides records of every Medicare claim submitted, including adjustment claims. SAFs contain final action claims data in which all adjustments have been resolved. These files contain information collected by Medicare to pay for health care services provided to a Medicare beneficiary. SAFs are available for each institutional (inpatient, outpatient, skilled nursing facility, hospice, or home health agency) and noninstitutional (physician and durable medical equipment providers) claim type. The record unit of SAFs is the claim (some episodes of care may have more than one claim).

MedPAR files contain inpatient hospital and skilled nursing facility (SNF) final action stay records. Each MedPAR record represents a stay in an inpatient hospital or SNF. An inpatient stay record summarizes all services rendered to a beneficiary from the time of admission to a facility, through discharge. Each MedPAR record may represent one claim or multiple claims, depending on the length of a beneficiary’s stay and the amount of inpatient services used throughout the stay.

The Denominator file contains demographic and enrollment information about each beneficiary enrolled in Medicare during a calendar year. The information in the Denominator file is frozen in March of the following calendar year. Some of the information contained in this file includes the beneficiary unique identifier, state and county codes, ZIP code, date of birth, date of death, sex, race, age, monthly entitlement indicators (for Medicare Part A, Medicare Part B, or Part A and Part B), reasons for entitlement, state buy-in indicators, and monthly managed care indicators (yes or no). The Denominator file is used to determine beneficiary demographic characteristics, entitlement, and beneficiary participation in Medicare managed care organizations (MCOs).

The Vital Status file contains demographic information about each beneficiary ever entitled to Medicare. Some of the information contained in this file includes the beneficiary unique identifier, state and county codes, ZIP code, date of birth, date of death, sex, race, and age.

The Group Health Plan (GHP) master file contains data on beneficiaries who are currently enrolled, or have ever been enrolled, in an MCO under contract with CMS. Each record represents one beneficiary, and each beneficiary has one record. Some of the information contained in this file includes the beneficiary unique identifier, state and county codes, date of birth, date of death, and managed care enrollment information such as dates of membership and MCO contract number.

##### Issues Affecting Interpretation

Because Medicare MCOs might not file claims, files based only on claims data will exclude care for persons enrolled in Medicare MCOs. In addition, to maintain a manageable file size, some files are based on a sample of enrollees rather than on all Medicare enrollees. Coding and the interpretation of Medicare coverage rules have also changed over the life of the Medicare program.

##### For More Information

See the CMS Research Data Assistance Center (ResDAC) website at: http://www.resdac.org and the CMS website at: http://www.cms.gov/Research-Statistics-Data-and-Systems/Research-Statistics-Data-and-Systems.html. (Also see Appendix II, Medicare.)

### Medicare Current Beneficiary Survey (MCBS)

#### Centers for Medicare & Medicaid Services (CMS)

##### Overview

MCBS produces nationally representative estimates of health and functional status, health care use and expenditures, health insurance coverage, and socioeconomic and demographic characteristics of Medicare beneficiaries. It is used to estimate expenditures and sources of payment for all services used by Medicare beneficiaries, including copayments, deductibles, and noncovered services; to ascertain all types of health insurance coverage and relate coverage to sources of payment; and to trace processes over time, such as changes in health status and the effects of program changes.

##### Coverage

MCBS is a continuous survey of a nationally representative sample of aged, institutionalized, and disabled Medicare beneficiaries.

##### Methodology

The overlapping panel design of the survey allows each sample person (or their proxies) to be interviewed three times a year for 4 years, whether he or she resides in the community or a facility or moves between the two settings, using the version of the questionnaire appropriate to the setting. Sample persons are interviewed using computer-assisted personal interviewing (CAPI) survey instruments. Because residents of long-term care facilities often are in poor health, information about institutionalized residents is collected from proxy respondents such as nurses and other primary caregivers affiliated with the facility. The sample is selected from the Medicare enrollment files, with oversampling among disabled persons under age 65 and among persons aged 85 and over.

MCBS has two components: the Cost and Use file and the Access to Care file. Medicare claims are linked to survey-reported events to produce the Cost and Use file, which provides complete expenditure and source-of-payment data on all health care services, including those not covered by Medicare. The Access to Care file contains information on beneficiaries’ access to health care, satisfaction with care, and usual source of care. The sample for this file represents the always enrolled population—those who participated in the Medicare program for the entire year. In contrast, the Cost and Use file represents the ever enrolled population, including those who entered Medicare and those who died during the year.

##### Sample Size and Response Rate

Each fall, about one-third of the MCBS sample is retired and roughly 6,000 new sample persons are included in the survey; the exact number chosen is based on projections of target samples of 12,000 persons with 3 years of cost and use information distributed appropriately across the sample cells. In the community, response rates for initial interviews are approximately 80%; once respondents have completed the first interview, their participation in subsequent rounds is 95% or more. In recent rounds, data have been collected from approximately 16,000 beneficiaries. Roughly 90% of the sample is made up of persons who live in the community, with the remaining persons living in long-term care facilities. Response rates for facility interviews approach 100%.

##### Issues Affecting Interpretation

Because only Medicare enrollees are included in MCBS, the survey excludes a small proportion of persons aged 65 and over who are not enrolled in Medicare. This should be noted when using MCBS to make estimates of the entire population aged 65 and over in the United States.

###### References

Adler GS. A profile of the Medicare Current Beneficiary Survey. Health Care Financ Rev. 1994;15(4):153-63. [pmid: 10138483].
Lo A, Chu A, Apodaca R. Redesign of the Medicare Current Beneficiary Survey sample. Rockville, MD. Westat, Inc. 2003. Available from: http://www.amstat.org/sections/srms/Proceedings/y2002/Files/JSM2002-000662.pdf.

##### For More Information

See the MCBS website at: http://www.cms.hhs.gov/MCBS.

### Monitoring the Future (MTF) Study

#### University of Michigan, supported by National Institute on Drug Abuse (NIDA)

##### Overview

MTF is an ongoing study that uses annual surveys to track the behaviors, attitudes, and values of U.S. secondary school students, college students, and adults through age 55. Data collected include lifetime, annual, and 30-day prevalence of use of many illegal drugs, inhalants, tobacco, and alcohol.

##### Coverage

MTF surveys a sample of 12th, 10th, and 8th graders in public and private high schools in the coterminous United States. Follow-up questionnaires are mailed to a sample of each graduating class for a number of years after their initial participation, to gather information on college students, young adults, and older adults.

##### Methodology

The survey design is a multistage random sample, with stage 1 being the selection of particular geographic areas, stage 2 the selection of one or more schools in each area, and stage 3 the selection of students within each school. Data are collected using self-administered questionnaires conducted in the classroom by representatives of the University of Michigan’s Institute for Social Research. Dropouts and students who are absent on the day of the survey are excluded. Recognizing that the dropout population is at higher risk for drug use, MTF was expanded in 1991 to include similar nationally representative samples of 8th and 10th graders, who have lower dropout rates than seniors and include future high-risk 12th grade dropouts. For more information on MTF adjustments for absentees and dropouts, see Johnston et al. (2013).

##### Sample Size and Response Rate

In 2013, a total of 41,675 students in 389 public and private schools in the coterminous United States participated. The annual senior samples comprised 13,180 12th graders in 126 public and private high schools nationwide. The 10th-grade samples involved 13,262 students in 120 schools, and the 8th-grade samples had 15,233 students in 143 schools. Student response rates were 90% for grade 8, 88% for grade 10, and 82% for grade 12 and have been relatively constant across time. Absentees constitute virtually all of the nonresponding students.

##### Issues Affecting Interpretation

Estimates of substance use among youth based on the National Survey on Drug Use & Health (NSDUH) are not directly comparable with estimates based on MTF and the Youth Risk Behavior Survey (YRBS). In addition to the fact that MTF excludes dropouts and absentees, rates are not directly comparable across these surveys because of differences in populations covered, sample design, questionnaires, interview setting, and data cleaning procedures. NSDUH collects data in residences, whereas MTF and YRBS collect data in school classrooms. In addition, NSDUH estimates are tabulated by age, whereas MTF and YRBS estimates are tabulated by grade, representing different ages as well as different populations.

###### References

Johnston LD, O’Malley PM, Bachman JG, Schulenberg JE, Miech RA. Monitoring the Future National Survey results on drug use: 1975–2013. Vol I: Secondary school students. Ann Arbor, MI. Institute for Social Research, The University of Michigan. 2014. Available from: http://www.monitoringthefuture.org//pubs/monographs/mtf-vol1_2013.pdf.
Cowan CD. Coverage, sample design, and weighting in three federal surveys. J Drug Issues. 2001;31(3):599-614.

##### For More Information

See the NIDA website at: http://www.nida.nih.gov/Infofax/HSYouthtrends.html and the MTF website at: http://www.monitoringthefuture.org.

### National Ambulatory Medical Care Survey (NAMCS)

#### CDC/NCHS

##### Overview

NAMCS provides national data about the provision and use of medical care services in office-based physician practices in the United States, using information collected from medical records. Data are collected on type of providers seen; reason for visit; diagnoses; drugs ordered, provided, or continued; and selected procedures and tests ordered or performed during the visit. Patient data include age, sex, race, and expected source of payment. Data are also collected on selected characteristics of physician practices.

##### Coverage

NAMCS covers patient encounters in the offices of nonfederally employed physicians classified by the American Medical Association (AMA) or American Osteopathic Association (AOA) as office-based patient care physicians in the United States. Patient encounters with physicians engaged in prepaid practices (health maintenance organizations [HMOs], independent practice organizations [IPAs], and other prepaid practices) are included in NAMCS. Excluded are visits to hospital-based physicians; visits to specialists in anesthesiology, pathology, or radiology; and visits to physicians who are principally engaged in teaching, research, or administration. Telephone contacts and nonoffice visits are also excluded. Starting in 2006, NAMCS includes visits to a separate sample of community health centers (CHCs).

##### Methodology

A multistage probability design is employed. Beginning in 1989, the first-stage sample consisted of 112 primary sampling units (PSUs), which were selected from about 1,900 such units into which the United States had been divided. In each sample PSU, a sample of practicing nonfederal, office-based physicians is selected from master files maintained by AMA and AOA. The final stage involves systematic random samples of office visits during randomly assigned 7-day reporting periods. Starting in 1989, the survey included all 50 states and D.C.

Starting in 2006, a dual-sampling procedure was used to select CHC physicians and nonphysician clinicians. First, the traditional NAMCS sample was selected using the methods described above. Second, information from the Health Resources and Services Administration and the Indian Health Service was used to select a sample of CHCs. Within CHCs, a maximum of three health care providers were selected, including physicians, physician assistants, nurse practitioners, or nurse midwives. After selection, CHC providers followed traditional NAMCS methods for selecting patient visits.

The U.S. Census Bureau acts as the data collection agent for NAMCS. Screening interviews are conducted by Census field representatives to obtain information about physicians’ office-based practices and to ensure that the practice is within the scope of the survey. Field representatives visit eligible physicians prior to their participation in the survey, to provide them with survey materials and instruct them on how to sample patient visits and complete patient record forms. Participants are asked to complete forms for a systematic random sample of approximately 30 office visits occurring during a randomly assigned 1-week period, but increasingly patient record forms are abstracted by field representatives.

Sample data are weighted to produce national estimates. The estimation procedure used in NAMCS has four basic components: inflation by the reciprocal of the probability of selection, adjustment for nonresponse, ratio adjustment to fixed totals, and weight smoothing.

##### Sample Size and Response Rate

In 2010, a sample of 3,525 physicians was selected: 2,406 were in-scope and 1,418 participated, for a response rate of 58%. Data were provided for 31,229 visits. The response rates have been modified to accommodate the mixture of one- and two-stage samples of providers.

##### Issues Affecting Interpretation

The NAMCS patient record form is modified approximately every 2–4 years to reflect changes in physician practice characteristics, patterns of care, and technological innovations. Examples of recent changes include increasing the number of drugs recorded on the patient record form and adding checkboxes for specific tests or procedures performed. Sample sizes vary by survey year. For some years it is suggested that analysts combine two or more years of data if they wish to examine relatively rare populations or events. Starting with Health, United States, 2005, data for survey years 2001–2002 were revised to be consistent with the weighting scheme introduced in the 2003 NAMCS data. For more information on the new weighting scheme, see Hing et al. (2005).

###### Reference

Hing E, Cherry DK, Woodwell DA. National Ambulatory Medical Care Survey: 2003 summary. Advance data from vital and health statistics; no 365. Hyattsville, MD. NCHS. 2005. Available from: http://www.cdc.gov/nchs/data/ad/ad365.pdf.

##### For More Information

See the National Health Care Surveys website at: http://www.cdc.gov/nchs/dhcs.htm and the Ambulatory Health Care Data website at: http://www.cdc.gov/nchs/ahcd.htm.

### National Compensation Survey (NCS)

#### Bureau of Labor Statistics (BLS)

##### Overview

NCS provides comprehensive measures of occupational earnings, compensation cost trends, benefit incidence, and detailed plan provisions based on surveys of a sample of employers.

##### Coverage

NCS provides information for the nation for the nine census divisions and for 152 selected areas (combined statistical areas, metropolitan statistical areas, micropolitan statistical areas, and county clusters). NCS includes both full-and part-time workers who are paid a wage or salary and includes data for the civilian economy, including both private industry and state and local government. It excludes agriculture, private household workers, the self-employed, and the federal government.

##### Methodology

NCS is conducted quarterly by BLS’ Office of Compensation and Working Conditions. The sample consists of approximately 152 areas that represent the nation’s metropolitan statistical areas and micropolitan statistical areas (as defined by the Office of Management and Budget [OMB]) and the remaining portions of the 50 states. The sample is selected using a three-stage design. The first stage involves the selection of geographic areas for the state and local government sample and the private industry sample. In the second stage, establishments are selected systematically, with the probability of selection proportionate to their relative employment size within sampled areas. Use of this technique means that the larger an establishment’s employment, the greater its chance of selection. The third stage of sampling is a probability sample of occupations within a sampled establishment. This step is performed by the BLS field economist during an interview with the respondent establishment in which selection of an occupation is based on probability of selection proportionate to employment in the establishment, and each occupation is classified under its corresponding major occupational group.

Data collection is conducted by BLS field economists. Data are gathered from each establishment on the primary business activity of the establishment; types of occupations; number of employees; wages, salaries, and benefits; hours of work; and duties and responsibilities. Data are collected for the pay period including the 12th day of the survey months of March, June, September, and December.

##### Sample Size and Response Rate

The sample consists of about 8,800 establishments in private industry and about 1,400 establishments in state and local government.

##### Issues Affecting Interpretation

Prior to 1999, estimates were based on multiple surveys which were replaced by NCS; therefore, trend analyses based on estimates prior to 1999 should be interpreted with care.

The state and local government sample is revised every 10 years and was replaced in its entirety in December 2007. As a result of this replacement, the number of state and local government occupations and establishments increased substantially. The private industry sample is rotated approximately every 5 years, which makes the sample more representative of the economy and reduces respondent burden. The sample is replaced on a cross-area, cross-establishment basis.

Compensation cost levels in state and local government should not be directly compared with levels in private industry. Differences between these sectors stem from factors such as variation in work activities and occupational structures.

###### References

Bureau of Labor Statistics. Employer costs for employee compensation—March 2014. [press release USDL–14– 1075]. Washington, DC. U.S. Department of Labor. 2014. June. 11. Available from: http://www.bls.gov/news.release/ecec.nr0.htm.
Wiatrowski WJ. The National Compensation Survey: Compensation statistics for the 21st century. Washington, DC. US Department of Labor, Bureau of Labor Statistics. Compensation and Working Conditions (CWC) Online 2000. Winter. 5-14. Available from: http://www.bls.gov/opub/mlr/cwc/the-national-compensation-survey-compensation-statistics-for-the-21st-century.pdf.
U.S. Bureau of Labor Statistics. BLS handbook of methods, Ch. 8: National compensation measures. 2007. Available from: http://www.bls.gov/opub/hom/pdf/homch8.pdf.

##### For More Information

See the NCS website at: http://www.bls.gov/ncs/.

### National Health and Nutrition Examination Survey (NHANES)

#### CDC/NCHS

##### Overview

NHANES is designed to assess the health and nutritional status of adults and children in the United States. The survey is unique in that it combines interviews and physical examinations. NHANES collects data on the prevalence of chronic diseases and conditions (including undiagnosed conditions) and on risk factors such as obesity, elevated serum cholesterol levels, hypertension, diet and nutritional status, and numerous other measures.

##### Coverage

NHANES III, conducted during 1988–1994, targets the civilian noninstitutionalized U.S. population aged 2 months and over. Beginning in 1999, NHANES has been conducted continuously and targets the civilian noninstitutionalized population.

##### Methodology

NHANES includes clinical examinations, selected medical and laboratory tests, and self-reported data. NHANES interviews persons in their homes and conducts medical examinations in a mobile examination center (MEC), including laboratory analysis of blood, urine, and other tissue samples. Medical examinations and laboratory tests follow very specific protocols and are standardized as much as possible to ensure comparability across sites and providers. In 1999–2002, as a substitute for the MEC examinations, a small number of survey participants received an abbreviated health examination in their homes if they were unable to come to the MEC.

The survey for NHANES III was conducted from 1988 to 1994 using a stratified, multistage probability design to sample the civilian U.S. population living in households. About 40,000 persons aged 2 months and over were selected and asked to complete an extensive interview and a physical examination. Participants were selected from households in 81 survey units across the United States. Children aged 2 months to 5 years, persons aged 60 and over, black persons, and persons of Mexican origin were oversampled to provide precise descriptive information on the health status of selected population groups in the United States.

Beginning in 1999, NHANES became a continuous annual survey, collecting data every year from a representative sample of the civilian noninstitutionalized U.S. population, newborns and older, through in-home personal interviews and physical examinations in the MEC. The sample design is a complex, multistage, clustered design using unequal probabilities of selection. The first-stage sample frame for continuous NHANES during 1999–2001 was the list of PSUs selected for the design of the National Health Interview Survey. Typically, an NHANES PSU is a county. For 2002, an independent sample of PSUs (based on current census data) was selected. This independent design was used for the period 2002–2006. In 2007–2010 and 2011–2014, the sample was redesigned. For 1999, because of a delay in the start of data collection, 12 distinct PSUs were in the annual sample. For each year in 2000–2010, 15 PSUs were selected. The within-PSU design involves forming secondary sampling units that are nested within census tracts, selecting dwelling units within secondary units, and then selecting sample persons within dwelling units. Selection of the final sample person involves differential probabilities of selection according to the demographic variables of sex (male or female), race and ethnicity (Hispanic, white, black, or all other persons), and age. Because of the differential probabilities of selection, dwelling units are screened for potential sample persons. For more information on the sample design for 1999–2006, see: http://www.cdc.gov/nchs/data/series/sr_02/sr02_155.pdf; and for the sample design for 2007–2010, see: http://www.cdc.gov/nchs/data/series/sr_02/sr02_160.pdf.

Beginning in 1999, NHANES oversampled low-income persons, adolescents aged 12–19, persons aged 60 and over, African American persons, and persons of Mexican origin. The sample for data years 1999–2006 was not designed to give a nationally representative sample for the total Hispanic population residing in the United States. Starting with 2007–2010 data collection, all Hispanic persons were oversampled, not just persons of Mexican origin, and adolescents were no longer oversampled. For more information on the sampling methodology and analytic guidance for 2007–2010, see: http://www.cdc.gov/nchs/data/nhanes/analyticnote_2007-2010.pdf.

In 2011–2012, the sampling design was changed and the following groups were oversampled: Hispanic persons; non-Hispanic black persons; non-Hispanic Asian persons; non-Hispanic white and other persons at or below 130% of poverty; and non-Hispanic white and other persons aged 80 and over. For more information on the 2011–2012 sample and analytic guidance, see: http://www.cdc.gov/nchs/data/nhanes/analytic_guidelines_11_12.pdf.

The estimation procedure used to produce national statistics for all NHANES involved inflation by the reciprocal of the probability of selection, adjustment for nonresponse, and poststratified ratio adjustment to population totals. Sampling errors also were estimated, to measure the reliability of the statistics.

##### Sample Size and Response Rate

Over the 6-year survey period of NHANES III, 39,695 persons were selected; the household interview response rate was 86% (33,994); and the medical examination response rate was 78% (30,818).

For NHANES 2009–2010, a total of 13,272 persons were identified, of which 79% (10,537) were interviewed and 77% (10,253) completed the health examination component. For NHANES 2011–2012, a total of 13,431 persons were identified, of which 73% (9,756) were interviewed and 70% (9,338) completed the health examination component. For more information on unweighted NHANES response rates and response weights using sample size weighted to Current Population Survey population totals, see: http://www.cdc.gov/nchs/nhanes/response_rates_CPS.htm.

##### Issues Affecting Interpretation

Data elements, laboratory tests performed, and the technological sophistication of medical examination and laboratory equipment have changed over time. Therefore, trend analyses should carefully examine how specific data elements were collected across the various survey years. Data files are revised periodically. If the file changes are minor and the impact on estimates small, then the data are not revised in Health, United States. Major data changes are incorporated.

Periodically, NHANES changes its sampling design to oversample different groups. Because the total sample size in any year is fixed due to operational constraints, sample sizes for the other oversampled groups (including Hispanic persons and non-low-income white and other persons) were decreased. Therefore, trend analyses on demographic subpopulations should be carefully evaluated to determine if the sample sizes meet the NHANES Analytic Guidelines. In general, any 2-year data cycle in NHANES can be combined with adjacent 2-year data cycles to create analytic data files based on 4 or more years of data in order to improve precision. However, because of the sample design change for 2011–2012, the data user should be aware of the implications if these data are combined with data from earlier survey cycles. Users are advised to examine their estimates carefully to see if the 4-year estimates (and sampling errors) are consistent with each set of 2-year estimates.

###### References

Ezzati TM, Massey JT, Waksberg J, et al. Sample design: Third National Health and Nutrition Examination Survey. NCHS. Vital Health Stat. 1992;2(113). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_113.pdf.
NCHS. Plan and operation of the Third National Health and Nutrition Examination Survey, 1988–94. Vital Health Stat. 1994;1(32). Available from: http://www.cdc.gov/nchs/data/series/sr_01/sr01_032.pdf.
Johnson CL, Paulose-Ram R, Ogden CL, et al. National Health and Nutrition Examination Survey: Analytic guidelines, 1999–2010. NCHS. Vital Health Stat. 2013;2(161). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_161.pdf.
NCHS. National Health and Nutrition Examination Survey: Analytic guidelines, 2011–2012. 2013. Available from: http://www.cdc.gov/nchs/data/nhanes/analytic_guidelines_11_12.pdf.

##### For More Information

See the NHANES website at: http://www.cdc.gov/nchs/nhanes.htm.

### National Health Expenditure Accounts (NHEA)

#### Centers for Medicare & Medicaid Services (CMS)

##### Overview

NHEA provide estimates of aggregate health care expenditures in the United States from 1960 onward. NHEA contain all of the main components of the health care system within a unified, mutually exclusive and exhaustive structure. The accounts measure spending for health care in the United States by type of good or service delivered (e.g., hospital care, physician and clinical services, or retail prescription drugs) and by the source of funds that pay for that care (e.g., private health insurance, Medicare, Medicaid, or out-of-pocket). A consistent set of definitions is used for health care goods and services and for sources of funds that finance health care expenditures, allowing for comparisons over time.

##### Methodology

The primary data sources used to estimate hospital care spending are the American Hospital Association (AHA) Annual Survey and the U.S. Census Bureau’s Services Annual Survey (SAS). These sources are supplemented by data on federal hospital spending. Expenditures for physician and clinical services, nursing care facilities and continuing care retirement communities, home health care, dentists, and the services of health care professionals (e.g., chiropractors, private duty nurses, therapists, and podiatrists) are estimated using data from SAS and the U.S. Census Bureau’s quinquennial Economic Census. The estimate of retail spending for prescription drugs is based on prescription drug data from the U.S. Census Bureau’s Census of Retail Trade and data from IMS Health (Danbury, CT), an organization that collects data on retail sales of prescription drugs.

Expenditures for durable and nondurable medical products purchased in retail outlets are based on input-output and personal consumption expenditure data (Bureau of Economic Analysis), Economic Census and Annual Retail Trade Survey (ARTS) data (U.S. Census Bureau), Consumer Expenditure Survey data (Bureau of Labor Statistics [BLS]), Medical Expenditure Panel Surveys (MEPS) data (Agency for Healthcare Research and Quality [AHRQ]), and over-the-counter sales data from Kline and Company, Inc. Durable and nondurable products provided to inpatients in hospitals or nursing homes, and those provided by licensed health professionals or through home health care agencies, are excluded from NHEA estimates of durable and nondurable medical products but are included with the expenditure estimates for the provider service category.

The Structures and Equipment component of NHEA includes estimates of the value of new construction put in place and new capital equipment (including software) purchased by the medical sector during the year. These estimates are based on a variety of data from the U.S. Census Bureau and the Bureau of Economic Analysis, including the Annual Capital Expenditures Survey, the C–30 Survey, and data from the National Income and Product Accounts.

Expenditures for noncommercial research are included in the Investment category of NHEA and are developed primarily from information gathered by the National Institutes of Health and the National Science Foundation. The cost of commercial research (such as by drug companies) is assumed to be embedded in the price charged for the product and therefore is not included in the noncommercial research category.

Private health insurance spending for health care goods and services is derived using data from the U.S. Census Bureau, the American Medical Association (AMA), the American Hospital Association (AHA), and IMS Health, as well as household data from surveys such as the National Medical Care Expenditure Survey (National Center for Health Services Research, 1987) and later, MEPS (AHRQ, 1996–2013). The net cost of private health insurance (which includes administrative costs, additions to reserves, rate credits and dividends, premium taxes, and net underwriting gains or losses) is estimated using data from A.M. Best (Oldwick, NJ), the National Association of Insurance Commissioners, BLS surveys on the cost of employer-sponsored health insurance and consumer expenditures, MEPS data for self-insured plans, data from privately funded surveys, and numerous consulting firms and private health insurance trade organizations.

Estimates of federal health care program spending (e.g., Medicare, Medicaid, and Department of Defense) were developed using administrative records maintained by the servicing agencies. Out-of-pocket spending (direct spending by consumers for copayments, coinsurance, deductibles, and payments for goods and services not covered by insurance) was estimated using data from SAS (U.S. Census Bureau), the Consumer Expenditure Survey (BLS), MEPS (AHRQ), the AHA Annual Survey, and data from IMS Health.

##### Issues Affecting Interpretation

Every 5 years, NHEA undergo a comprehensive revision that includes the incorporation of newly available source data, methodological and definitional changes, and benchmark estimates from the Economic Census. During these comprehensive revisions, the entire NHEA time series is opened for revision. In addition to these changes, during the 2009 comprehensive revision, the classification structure of NHEA was changed to more clearly align programs and payers with the current health care system. CMS (2010).

###### References

Hartman M, Martin AB, Lassman D, Catlin A. the National Health Expenditure Accounts Team. National health spending in 2013: Growth slows, remains in step with the overall economy. Health Aff (Millwood). 2015;34(1):150-160. [pmid: 25472958].
Martin AB, Hartman M, Whittle L, Catlin A. National Health Expenditure Accounts Team. National health spending in 2012: Rate of health spending remained low for the fourth consecutive year. Health Aff (Millwood). 2014;33(1):67-77. [pmid: 24395937].
Centers for Medicare & Medicaid Services. National Health Expenditure Accounts: Methodology paper, 2013: Definitions, sources, and methods. Baltimore, MD. CMS. 2015. Available from: http://www.cms.gov/Research-Statistics-Data-and-Systems/Statistics-Trends-and-Reports/NationalHealthExpendData/Downloads/DSM-13.pdf.
Centers for Medicare & Medicaid Services. Summary of National Health Expenditure Account 2009 comprehensive revisions. Baltimore, MD. CMS. 2010. Available from: http://www.cms.gov/Research-Statistics-Data-and-Systems/Statistics-Trends-and-Reports/NationalHealthExpendData/Downloads/benchmark2009.pdf.

##### For More Information

See the CMS National Health Expenditure Accounts website at: http://www.cms.gov/Research-Statistics-Data-and-Systems/Statistics-Trends-and-Reports/NationalHealthExpendData/NationalHealthAccountsHistorical.html.

### National Health Interview Survey (NHIS)

#### CDC/NCHS

##### Overview

NHIS monitors the health of the U.S. population through the collection and analysis of data on a broad range of health topics. A major strength of this survey lies in the ability to analyze health measures by many demographic and socioeconomic characteristics. During household interviews, NHIS obtains information on activity limitation, illnesses, injuries, chronic conditions, health insurance coverage (or lack thereof), utilization of health care, and other health topics.

##### Coverage

The survey covers the civilian noninstitutionalized population of the United States. Among those excluded are patients in long-term care facilities, persons on active duty with the Armed Forces (although their dependents are included), incarcerated persons, and U.S. nationals living in foreign countries.

##### Methodology

NHIS is a cross-sectional household interview survey. Sampling and interviewing are continuous throughout each year. The sampling plan follows a multistage area probability design that permits the representative sampling of households. Traditionally, the sample for NHIS is redesigned and redrawn about every 10 years to better measure the changing U.S. population and to meet new survey objectives. A new sample design was implemented in the 2006 survey. The fundamental structure of the 2006 design is very similar to the previous design for the 1995–2005 surveys. Only the current sampling plan covering design years 2006–2015 is addressed here. The first stage of the current sampling plan consists of a sample of 428 primary sampling units (PSUs) drawn from approximately 1,900 geographically defined PSUs that cover the 50 states and D.C. A PSU consists of a county, a small group of contiguous counties, or a metropolitan statistical area.

Within a PSU, two types of second-stage units are used: area segments and permit segments. Area segments are defined geographically and contain an expected 8, 12, or 16 addresses. Permit segments cover housing units built after the 2000 census. The permit segments are defined using updated lists of building permits issued in the PSU since 2000 and contain an expected four addresses. Within each segment, all occupied households at the sample addresses are targeted for interview.

The total NHIS sample of PSUs is subdivided into four separate panels, or subdesigns, such that each panel is a representative sample of the U.S. population. This design feature has a number of advantages, including flexibility for the total sample size. The households selected for interview each week in NHIS are a probability sample representative of the target population.

Oversampling of the black and Hispanic populations was retained in the 2006–2015 design to allow for more precise estimation of health characteristics in these populations. The current sample design also oversamples the Asian population. In addition, the sample adult selection process was revised so that when black, Hispanic, or Asian persons aged 65 and over are present, they have an increased chance of being selected as the sample adult.

The current NHIS questionnaire, implemented in 1997, has two basic parts: a Basic Module or Core and one or more supplements that vary by year. The Core remains largely unchanged from year to year and allows for trend analysis and for data from more than 1 year to be pooled to increase the sample size for analytic purposes. The Core contains three components: the Family, the Sample Adult, and the Sample Child. The Family component collects information on everyone in the family. From each family in NHIS, one sample adult and for families with children under age 18, one sample child are randomly selected to participate in the Sample Adult and Sample Child questionnaires. For children, information is provided by a knowledgeable family member aged 18 or over residing in the household. Because some health issues are different for children and adults, these two questionnaires differ in some items, but both collect basic information on health status, use of health care services, health conditions, and health behaviors.

##### Sample Size and Response Rate

The NHIS sample size varies from year to year. It may be reduced for budgetary reasons or may be augmented if supplementary funding is available. Between 1997 and 2005, the sample numbered about 100,000 persons annually, with about 30,000–36,000 persons participating in the Sample Adult and about 12,000–14,000 in the Sample Child questionnaires. In the 2006–2015 redesign, the NHIS sample was reduced by 13% compared with the 1995–2005 design. With four sample panels and no sample cuts or augmentations, the expected annual NHIS sample size (completed interviews) during survey years 2006–2010 was, on average, 37,000 households containing about 81,000 persons.

In 2011–2013, the NHIS sample size was augmented in 32 states and D.C. The main goal of the augmentation was to increase the number of states for which reliable state-level estimates can be made. In 2011, the sample size was augmented by approximately 13%; in 2012, by approximately 21%; and in 2013, by approximately 18%.

In 2011, the sample numbered 101,875 persons, with 33,014 persons participating in the Sample Adult and 12,850 in the Sample Child questionnaires. In 2011, the total household response rate was 82%. The final response rate was 66% for the Sample Adult file and 75% for the Sample Child file.

In 2012, the sample numbered 108,131 persons, with 34,525 persons participating in the Sample Adult and 13,275 in the Sample Child questionnaires. In 2012, the total household response rate was 78%. The final response rate was 61% for the Sample Adult file and 70% for the Sample Child file.

In 2013, the sample numbered 104,520 persons, with 34,557 persons participating in the Sample Adult and 12,860 in the Sample Child questionnaires. In 2013, the total household response rate was 76%. The final response rate was 61% for the Sample Adult file and 69% for the Sample Child file.

##### Issues Affecting Interpretation

In 1997, the questionnaire was redesigned: some basic concepts were changed, and other concepts were measured in different ways. For some questions there was a change in the reference period. Also in 1997, the collection methodology changed from paper-and-pencil questionnaires to computer-assisted personal interviewing (CAPI). Because of the major redesign of the questionnaire in 1997, most NHIS trend tables in Health, United States begin with 1997 data. Starting with Health, United States, 2005, estimates for 2000–2002 were revised to use 2000-based weights and differ from previous editions of Health, United States that used 1990-based weights for those data years. The weights available on the public-use NHIS files for 2000–2002 are 1990-based. Data for 2003–2011 use weights derived from the 2000 census. Data for 2012 and beyond use weights derived from the 2010 census. In 2006–2010, the sample size was reduced, and this is associated with slightly larger variance estimates than in other years when a larger sample was fielded. Starting in 2010, a geographic nonresponse adjustment was made to both the sample adult weight and the sample child weight. See Moriarity (2009).

###### Reference

Moriarity C. 2009 National Health Interview Survey sample adult and sample child nonresponse bias analysis. Hyattsville, MD. NCHS. 2010. Available from: http://www.cdc.gov/nchs/data/nhis/nr_bias_analysis_report_2009_NHIS.pdf.

##### For More Information

See the NHIS website at: http://www.cdc.gov/nchs/nhis.htm.

### National HIV Surveillance System

#### CDC/National Center for HIV/AIDS, Viral Hepatitis, STD, and TB Prevention (NCHHSTP)

##### Overview

Human immunodeficiency virus (HIV) surveillance data are used to detect and monitor cases of HIV infection in the United States, identify epidemiologic trends, identify unusual cases requiring follow-up, and inform public health efforts to prevent and control the disease. Data collected on persons diagnosed with HIV infection include age, sex, race, ethnicity, mode of exposure, and geographic region.

##### Coverage

All 50 states, D.C., and six U.S. dependent areas (American Samoa, Guam, Northern Mariana Islands, Puerto Rico, Republic of Palau, and the U.S. Virgin Islands) report confirmed diagnoses of HIV infection to CDC using a uniform surveillance case definition and case report form. As of April 2008, all reporting areas had implemented confidential, name-based HIV infection reporting and agreed to participate in CDC’s National HIV Surveillance System. Health, United States only presents data for the 50 states and the six U.S. dependent areas (American Samoa, Guam, Northern Mariana Islands, Puerto Rico, Republic of Palau, and the U.S. Virgin Islands).

##### Methodology

HIV surveillance is conducted by health departments in each state or dependent area and D.C. Although surveillance activities range from passive to active, most areas employ multifaceted active surveillance programs that include five major reporting sources of HIV information: hospitals and hospital-based physicians, physicians in nonhospital practice, public and private clinics, medical record systems (death certificates, tumor registries, hospital discharge abstracts, and communicable disease reports), and laboratories. Using a standard confidential case report form, the health departments collect information that is then transmitted electronically, without personal identifiers, to CDC.

The statistical adjustment of data on diagnoses of HIV infection (including stage 3, AIDS) is based on estimates of reporting-delay distributions, which are calculated by using a modified semiparametric life table statistical procedure. This procedure takes into account differences in reporting delays due to sex, race/ethnicity, and HIV transmission categories; reporting city, state, or territory; geographic region; size of the metropolitan statistical area; and type of facility where the diagnosis was made. HIV surveillance data are provisional and are updated annually.

##### Issues Affecting Interpretation

Although the completeness of reporting of cases of HIV infection to state and local health departments differs by geographic region and patient population, studies conducted by state and local health departments indicate that the reporting of cases of HIV infection in most areas of the United States is more than 80% complete. To assess trends in cases of HIV infection and deaths, it is preferable to use case data adjusted for reporting delays and presented by year of diagnosis, rather than straight counts of cases presented by year of report.

###### Reference

CDC. HIV surveillance report. Atlanta, GA. [published annually]. Available from: http://www.cdc.gov/hiv/library/reports/surveillance/index.html.

##### For More Information

See the NCHHSTP website at: http://www.cdc.gov/nchhstp.

### National Hospital Ambulatory Medical Care Survey (NHAMCS)

#### CDC/NCHS

##### Overview

NHAMCS provides national data on the provision and use of medical care services in hospital emergency and outpatient departments, using information collected from medical records. Data are collected on types of providers seen; reason for visit; diagnoses; drugs ordered, provided, or continued; and selected procedures and tests performed during the visit. Patient data include age, sex, race, and expected source of payment. Data are also collected on selected characteristics of the hospitals included in the survey.

##### Coverage

NHAMCS covers visits to emergency departments (EDs) and outpatient departments (OPDs) of nonfederal, short-stay, or general hospitals in the United States. Telephone contacts are excluded. Starting in 2009, the survey includes visits to hospital-based ambulatory surgery centers (ASCs). Starting in 2010, visits to freestanding ASCs are included.

##### Methodology

The four-stage probability sample design used in NHAMCS involves samples of (a) geographically defined primary sampling units (PSUs), (b) hospitals within PSUs, (c) clinics or emergency service areas within OPDs or EDs, and (d) patient visits within clinics or emergency service areas. EDs are treated as their own stratum, and all service areas within EDs are included. The first-stage sample of NHAMCS consists of 112 PSUs selected from 1,900 such units that make up the United States. Within PSUs, 600 general and short-stay hospitals were sampled and assigned to 1 of 16 panels. In any given year, 13 panels are included. Each panel is assigned to a 4-week reporting period during the survey year.

In the NHAMCS OPD, a clinic is defined as an administrative unit of the OPD in which ambulatory medical care is provided under the supervision of a physician. Clinics where only ancillary services (e.g., radiology, laboratory services, physical rehabilitation, renal dialysis, and pharmacy) are provided, or other settings in which physician services are not typically provided, are considered out of scope. If a hospital OPD has five or fewer in-scope clinics, all are included in the sample. If an OPD has more than five clinics, the clinics are assigned to one of six specialty groups: general medicine, surgery, pediatrics, obstetrics and gynecology, substance abuse, and other. Within these specialty groups, clinics are grouped into clinic sampling units (SUs). A clinic SU is generally one clinic, except when a clinic expects fewer than 30 visits. In that case, it is grouped with one or more other clinics to form a clinic SU. If the grouped SU is selected, all clinics included in that SU are included in the sample. Prior to 2001, generally a sample of five clinic SUs was selected per hospital, based on probability proportional to the total expected number of patient visits to the clinic during the assigned 4-week reporting period. Starting in 2001, clinic sampling within each hospital was stratified. If an OPD had more than five clinics, two clinic SUs were selected from each of the six specialty groups with a probability proportional to the total expected number of visits to the clinic. The change was made to ensure that at least two SUs were sampled from each of the specialty group strata.

The U.S. Census Bureau acts as the data collection agent for NHAMCS. Census field representatives contact sample hospitals to determine whether they have a 24-hour ED or an OPD that offers physician services. Visits to eligible EDs and OPDs are systematically sampled over the 4-week reporting period such that about 100 ED encounters and about 150–200 OPD encounters are selected. Hospital staff are asked to complete patient record forms (PRFs) for each sampled visit, but census field representatives typically abstract data for approximately two-thirds of these visits.

Sample data are weighted to produce national estimates. The estimation procedure used in NHAMCS has three basic components: inflation by the reciprocal of the probability of selection, adjustment for nonresponse, and population weighting ratio adjustment.

##### Sample Size and Response Rate

In any given year, the hospital sample consists of approximately 500 hospitals, of which 80% have EDs and about one-half have eligible OPDs. Typically, about 1,000 clinics are selected from participating hospital OPDs.

In 2011, the number of PRFs completed for EDs was 31,084 and for OPDs was 32,233, and the hospital response rate was 80% for EDs and 67% for OPDs.

##### Issues Affecting Interpretation

The NHAMCS PRF is modified approximately every 2 to 4 years to reflect changes in physician practice characteristics, patterns of care, and technological innovations. Examples of recent changes include an increase in the number of drugs recorded on the PRF and adding checkboxes for specific tests or procedures performed.

###### Reference

McCaig LF, McLemore T. Plan and operation of the National Hospital Ambulatory Medical Care Survey. NCHS. Vital Health Stat. 1994;1(34). Available from: http://www.cdc.gov/nchs/data/series/sr_01/sr01_034acc.pdf.

##### For More Information

See the National Health Care Surveys website at: http://www.cdc.gov/nchs/dhcs.htm and the Ambulatory Health Care Data website at: http://www.cdc.gov/nchs/ahcd.htm.

### National Hospital Discharge Survey (NHDS)

#### CDC/NCHS

##### Overview

NHDS collected and produced national estimates on characteristics of inpatient stays in nonfederal, short-stay hospitals in the United States annually from 1965 through 2010. Patient information collected included demographics, length of stay, diagnoses, and procedures. Hospital characteristics collected included region, ownership, and bed size.

##### Coverage

The survey design covered the 50 states and D.C. Included in the survey were hospitals with an average length of stay of less than 30 days for all inpatients, general hospitals, and children’s general hospitals. Excluded were federal, military, and Department of Veterans Affairs hospitals, as well as hospital units of institutions (such as prison hospitals) and hospitals with fewer than six beds staffed for patient use. All discharged patients from in-scope hospitals were included in the survey; however, data for newborns were not included in Health, United States.

##### Methodology

The NHDS design implemented in 1965 continued through 1987, and a redesign with a new sample of hospitals, fielded in 1988, was in place until 2010 when the survey was redesigned.

Data collection was conducted by manual abstraction of patient information from sampled medical records. Sample selection and transcription of information from inpatient medical records to NHDS survey forms were performed by hospital staff, representatives of NCHS, or both. In 1985, a second data collection procedure was introduced that involved the purchase of computer data files from commercial abstracting services, state data systems, hospitals, or hospital associations that contained automated discharge data for some hospitals participating in NHDS. Discharges on these computer files were subjected to the NHDS sampling specifications, as well as the computer edits and estimation procedures.

Under the 1988 redesign, hospitals were selected using a modified three-stage stratified design. Units selected at the first stage consisted of primary sampling units (PSUs) used for the 1985–1994 National Health Interview Survey, which are geographic areas such as counties or townships. Hospitals within PSUs were selected at the second stage. Strata at this stage were defined by geographic region, PSU size, abstracting service status, and hospital specialty-size groups. Within these strata, hospitals were selected with probabilities proportional to their annual number of discharges. At the third stage, a sample of discharges was selected by a systematic random sampling technique. The sampling rate was determined by the hospital’s sampling stratum and the type of data collection system (manual or automated) used. Discharge records from hospitals submitting data from commercial abstracting services and selected state data systems were arrayed by primary diagnoses, patient sex and age group, and date of discharge, before sampling.

The NHDS hospital sample was generally updated every 3 years by continuing the sampling process among hospitals that became eligible for the survey during the intervening years and by excluding hospitals that were no longer eligible. This updating was conducted in 1991, 1994, 1997, 2000, 2003, and 2006.

The basic unit of estimation for NHDS is a sampled discharge. The basic estimation procedure involves inflation by the reciprocal of the probability of selection. Adjustments are made for nonresponding hospitals and discharges, and a postratio adjustment to fixed totals is employed.

##### Sample Size and Response Rate

Due to funding limitations, the 2008–2010 survey sample sizes were cut in half. In 2009, 239 hospitals were selected: 238 were within scope, 205 participated (for an unweighted response rate of 86%), and data were collected from medical records for approximately 162,000 discharges. In 2010, 239 hospitals were selected: 236 were within scope, 203 participated (for an unweighted response rate of 86%), and data were collected from medical records for approximately 152,000 discharges.

##### Issues Affecting Interpretation

NHDS was redesigned in 1988, and the sample size was cut in half for the 2008–2010 surveys; therefore, caution is required in comparing trend data from before and after these changes. In particular, the smaller sample size for the 2008–2010 surveys has resulted in larger standard error estimates for statistics produced by the survey, and in some cases the relative standard errors have doubled. Special care should be taken when making estimates for children under age 15 and for the West Census region because a review of a variety of estimates for these populations showed that many do not meet NCHS standards of reliability. Annual modifications to the International Classification of Diseases, 9th Revision, Clinical Modification (ICD–9–CM) may affect diagnosis and procedure categories. (See Appendix II, International Classification of Diseases, 9th Revision, Clinical Modification [ICD–9–CM]; Table X; Table XI.)

Hospital utilization rates per 10,000 population were computed using estimates of the civilian population of the United States as of July 1 of each year. Rates for 1990–1999 use postcensal estimates of the civilian population based on the 1990 census, adjusted for net underenumeration using the 1990 National Population Adjustment Matrix from the U.S. Census Bureau. The estimates for 2000 and beyond that appear in Health, United States, 2003 and later editions were calculated using estimates of the civilian population based on the 2000 census, and therefore are not strictly comparable with postcensal rates calculated for the 1990s. (See Appendix I, Population Census and Population Estimates.)

###### References

NCHS. Data highlights from the National Hospital Discharge Survey. Available from: http://www.cdc.gov/nchs/nhds/nhds_tables.htm#number.
NCHS. National Hospital Discharge Survey: 2010 Public Use Data File documentation. Available from: ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Dataset_Documentation/NHDS/NHDS_2010_Documentation.pdf.
Dennison C, Pokras R. Design and operation of the National Hospital Discharge Survey: 1988 Redesign. NCHS. Vital Health Stat. 2000;1(39). Available from: http://www.cdc.gov/nchs/data/series/sr_01/sr01_039.pdf.

##### For More Information

See the National Health Care Surveys website at: http://www.cdc.gov/nchs/dhcs.htm and the National Hospital Discharge Survey website at: http://www.cdc.gov/nchs/nhds.htm.

### National Immunization Survey (NIS)

#### CDC/National Center for Immunization and Respiratory Diseases (NCIRD) and NCHS

##### Overview

NIS is a continuing nationwide telephone sample survey to monitor vaccination coverage rates among children aged 19–35 months and among teenagers (NIS-Teen) aged 13–17. Data collection for children aged 19–35 months started in 1994, and data collection for teenagers aged 13–17 started in 2004.

##### Coverage

Children aged 19–35 months and adolescents aged 13–17 in the civilian noninstitutionalized population are represented in this survey. Estimates of vaccine-specific coverage are available for the nation, states, and selected urban areas.

##### Methodology

NIS is a nationwide telephone sample survey of households with age-eligible children. The survey uses a two-phase sample design. First, a random-digit-dialing sample of telephone numbers is drawn. When households with age-eligible children are contacted, the interviewer collects information on the vaccinations received by all age-eligible children and obtains permission to contact the children’s vaccination providers. Second, identified providers are sent vaccination history questionnaires by mail. Providers’ responses are compared with information obtained from households to provide a more accurate estimate of vaccination coverage levels. Final estimates are adjusted for households without telephones and for nonresponse. NIS-Teen followed the same sample design and data collection procedures as NIS except that only one age-eligible adolescent was selected from each household for data collection.

Starting in 2011, the NIS sampling frame was expanded from a single-landline frame to dual-landline and cellular telephone sampling frames. This change increased the representativeness of the sample characteristics but had little effect on the final 2011 NIS and NIS-Teen national estimates of vaccination coverage overall and when stratified by poverty status. See: CDC. Announcement: Addition of households with only cellular telephone service to the National Immunization Survey, 2011. MMWR 2012;61(34):685. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm6134a5.htm?s_cid=mm6134a5_e%0d%0a.

##### Sample Size and Response Rate

In 2013, the Council of American Survey Research Organizations (CASRO) response rate for the NIS landline sample was 62.3% and 30.5% for the cellular telephone sample. Of the 4,963 age-eligible children with completed household interviews from the landline sample, 3,152 (63.5%) had adequate provider data. From the cellular telephone sample, 10,459 (59.8%) of the 17,499 eligible children with completed household interviews had adequate provider data.

The CASRO response rate for the 2013 NIS-Teen landline sample was 51.1% and 23.3% for the cellular telephone sample. Of the 10,148 age-eligible adolescents with completed household interviews from the landline sample, 6,039 (59.5%) had adequate provider data. From the cellular telephone sample, 12,225 (54.5%) of the 22,448 eligible adolescents with completed household interviews had adequate provider data.

##### Issues Affecting Interpretation

For data years 1998, 2002, 2004, and 2005, slight modifications to the estimation procedure were implemented to obtain vaccination coverage rates from the provider data. Published estimates of vaccination coverage based on NIS data for years prior to 1998 (e.g., estimates published in Morbidity and Mortality Weekly Report [MMWR] articles) may differ slightly from estimates published in Health, United States and on the NIS website for the same data. All released public-use data files include the sampling weights using the revised estimation procedure.

The findings in recent years are subject to several limitations. Data year 2011 was the first year that the NIS and NIS-Teen used a dual-frame sampling scheme that included landline and cellular telephone households. Estimates from 2011 and subsequent years might not be comparable with those from prior to 2011 when surveys were conducted via landline telephone only. NIS is a telephone survey, and statistical adjustments might not compensate fully for nonresponse and for households without landline telephones prior to 2011. Underestimates of vaccination coverage might have resulted in exclusive use of provider-reported vaccination histories because completeness of records is unknown. Finally, although national coverage estimates are precise, annual estimates and trends for state and local areas should be interpreted with caution because of smaller sample sizes and wider confidence intervals.

Before January 2009, NIS did not distinguish between Hib vaccine production types; therefore, children who received three doses of a vaccine product that requires four doses were misclassified as fully vaccinated. For more information, see “Changes in measurement of Haemophilus influenzae serotype b (Hib) vaccination coverage—National Immunization Survey, United States, 2009” (2010).

###### References

CDC. National, state, and local area vaccination coverage among children aged 19–35 months—United States, 2012. MMWR. 2013;62(36):733-740. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm6236a1.htm.
CDC. National and state vaccination coverage among adolescents aged 13–17 years—United States, 2012. MMWR. 2013;62(34):685-693. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm6234a1.htm.
Smith PJ, Hoaglin DC, Battaglia MP, et al. Statistical methodology of the National Immunization Survey, 1994–2002. NCHS. Vital Health Stat. 2005;2(138). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_138.pdf.
CDC. Announcement: Addition of households with only cellular telephone service to the National Immunization Survey. 2011. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm6134a5.htm?s_cid=mm6134a5_e%0d%0a.
CDC. Changes in measurement of Haemophilus influenzae serotype b (Hib) vaccination coverage—National Immunization Survey, United States, 2009. MMWR. 2010;59(33):1069-72. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm5933a3.htm?s_cid=mm5933a3_e%%0d%0a.

##### For More Information

See the NIS website at: http://www.cdc.gov/nchs/nis.htm.

### National Income and Product Accounts (NIPA)

#### Bureau of Economic Analysis (BEA)

##### Overview

NIPA are a set of economic accounts that provide detailed measures of the value and composition of national output and the incomes generated in the production of that output. Essentially, NIPA provide a detailed snapshot of the myriad transactions that make up the economy—buying and selling goods and services, hiring of labor, investing, renting property, paying taxes, and the like. NIPA estimates show U.S. production, distribution, consumption, investment, and saving.

The best-known NIPA measure is the gross domestic product (GDP), which is defined as the market value of the goods and services produced by labor and property located in the United States. NIPA calculate GDP as the sum of familiar final expenditure components: personal consumption expenditures, private investment, government spending (consumption and investment), and net exports. However, GDP is just one of many economic measures presented in NIPA. Other key NIPA estimates presented in Health, United States include the implicit price deflator for GDP and federal and state and local government expenditures.

The conceptual framework of NIPA is illustrated by seven summary accounts: the domestic income and product account, the private enterprise income account, the personal income and outlay account, the government receipts and expenditures account, the foreign transactions current account, the domestic capital account, and the foreign transactions capital account. These summary accounts record a use (or expenditure) in one account for one sector and a corresponding source (or receipt) in an account of another sector or of the same sector. This integrated system provides a comprehensive measure of economic activity in a consistently defined framework without double counting.

##### Coverage

Source data for NIPA domestic estimates cover all 50 states and D.C. The U.S. national income and product statistics were first presented as part of a complete and consistent double-entry accounting system in the summer of 1947.

##### Methodology

NIPA estimates are revised on a quarterly, annual, and quinquennial basis. For GDP and most other NIPA series, a set of three current quarterly estimates is released each year. Quarterly estimates provide the first look at the path of U.S. economic activity. Annual revisions of NIPA are usually carried out each summer. These revisions incorporate source data that are based on more extensive annual surveys, on annual data from other sources, and on later revisions to the monthly and quarterly source data, and they generally cover the three previous calendar years.

Comprehensive revisions are carried out at about 5-year intervals and may result in revisions that extend back many years. These estimates incorporate all of the best available source data, such as data from the quinquennial U.S. Economic Census.

NIPA measures are built up from a wide range of source data using a variety of estimating methods. To ensure consistency and accuracy, NIPA use various adjustment and estimation techniques to estimate data. Three general types of adjustments are made to the source data that are incorporated into the NIPA estimates. The first consists of adjustments that are needed so that the data conform to appropriate NIPA concepts and definitions. The second type of adjustment involves filling gaps in coverage. The third type of adjustment involves time of recording and valuation. Source data must occasionally be adjusted to account for special circumstances that affect the accuracy of the data. For example, quarterly and monthly NIPA estimates are seasonally adjusted at the detailed-series level when the series demonstrate statistically significant seasonal patterns. Source data may also be used as indicators to extrapolate annual estimates. For more information, see “An introduction to the National Income and Product Accounts methodology papers: U.S. National Income and Product Accounts,” available from: http://www.bea.gov/scb/pdf/national/nipa/methpap/mpi1_0907.pdf; and “Concepts and methods of the U.S. National Income and Product Accounts,” available from: http://www.bea.gov/national/pdf/chapters1-4.pdf.

##### Issues Affecting Interpretation

NIPA source data and estimates are revised frequently. Data are released at different times, estimates are updated as they become available, new concepts and definitions are incorporated, and source data may change due to improvements in collection and new methodologies. As a result, major estimates such as GDP and its major components undergo frequent revision, and historical data are changed. For more information, see the BEA (NIPA) website at: http://www.bea.gov/national/an1.htm#2012AnnualRevision.

###### Reference

U.S. Bureau of Economic Analysis. A guide to the National Income and Product Accounts of the United States. Washington, DC. BEA. 2006. Available from: http://www.bea.gov/national/pdf/nipaguid.pdf.

##### For More Information

See the BEA (NIPA) website at: http://www.bea.gov/national/index.htm.

### National Medical Expenditure Survey (NMES)—See Appendix I, Medical Expenditure Panel Survey (MEPS)

### National Notifiable Diseases Surveillance System (NNDSS)

#### CDC

##### Overview

The CDC National Notifiable Diseases Surveillance System (NNDSS) is a nationwide collaboration that enables all levels of public health (local, state, territorial, federal, and international) to share health information to monitor, control, and prevent the occurrence and spread of state-reportable and nationally notifiable infectious and some noninfectious diseases and conditions. NNDSS is a multifaceted program that includes the surveillance system for collection, analysis, and sharing of health data, resources, and information about policies and standards, at the local, state, and national levels. NNDSS provides weekly provisional and annual finalized information on the occurrence of diseases defined as notifiable by the Council of State and Territorial Epidemiologists (CSTE). Data include incidence of reportable diseases, which are nationally notifiable using uniform surveillance case definitions.

##### Coverage

Notifiable disease reports are received from health departments in the 50 states, five territories, D.C., and New York City. Policies for reporting notifiable disease cases can vary by disease or reporting jurisdiction, depending on case status classification (i.e., confirmed, probable, or suspect).

##### Methodology

CDC, in partnership with CSTE, administers NNDSS. Reportable disease surveillance is conducted by public health practitioners at local, state, and national levels to support disease prevention and control and then data on a subset of reportable conditions which have been designated nationally notifiable are submitted to CDC without personal identifiers. The system also provides annual summaries of the finalized data. CSTE and CDC annually review the status of national infectious disease surveillance and recommend additions or deletions to the list of nationally notifiable diseases, based on the need to respond to emerging priorities. For example, Q fever and tularemia became nationally notifiable in 2000. However, reporting nationally notifiable diseases to CDC is voluntary. Because reporting is currently mandated by law or regulation only at the local and state levels, the list of diseases that are considered reportable varies by state. For example, reporting of cyclosporiasis to CDC is not done by some states in which this disease is not reportable to local or state authorities.

State epidemiologists report cases of nationally notifiable diseases to CDC, which tabulates and publishes these data in Morbidity and Mortality Weekly Report (MMWR) and in Summary of Notifiable Diseases, United States (before 1985, titled Annual Summary).

##### Issues Affecting Interpretation

NNDSS data must be interpreted in light of reporting practices. Some diseases that cause severe clinical illness (for example, plague and rabies) are likely reported accurately if diagnosed by a clinician. However, persons who have diseases that are clinically mild and infrequently associated with serious consequences (e.g., salmonellosis) may not seek medical care from a health care provider. Even if these less severe diseases are diagnosed, they are less likely to be reported.

The degree of completeness of data reporting is also influenced by the diagnostic facilities available, the control measures in effect, public awareness of a specific disease, and the interests, resources, and priorities of state and local officials responsible for disease control and public health surveillance. Finally, factors such as changes in case definitions for public health surveillance, introduction of new diagnostic tests, or discovery of new disease entities can cause changes in disease reporting that are independent of the true incidence of disease.

###### Reference

CDC. Summary of notifiable diseases—United States, 2012. MMWR. 2014;61(53):1-121. Available from http://www.cdc.gov/mmwr/mmwr_nd/index.html.

##### For More Information

See the NNDSS website at: http://wwwn.cdc.gov/nndss/.

### National Survey of Family Growth (NSFG)

#### CDC/NCHS

##### Overview

NSFG gathers information on family life, marriage and divorce, pregnancy, infertility, use of contraception, and men’s and women’s health. NSFG provides national data on factors affecting birth and pregnancy rates, adoption, and maternal and infant health. Data collected include sexual activity, marriage, divorce and remarriage, unmarried cohabitation, forced sexual intercourse, contraception and sterilization, infertility, breastfeeding, pregnancy loss, low birthweight, and use of medical care for family planning and infertility.

##### Coverage

NSFG in 1982, 1988, and 1995 included women aged 15–44 in the civilian noninstitutionalized population of the U.S. The 2002, 2006–2010, and 2011–2013 NSFG included both men and women aged 15–44 in the household population of the United States. The household population of the United States refers to the civilian noninstitutionalized population and active-duty military personnel who are not living on military bases.

##### Methodology

The 2006–2010 and 2011–2013 NSFG sample design consisted of five stages of selection: primary sampling units (PSUs), blocks or segments, housing units, one eligible person per housing unit, and housing units or persons for phase 2 data collection (intended to raise response rates and correct any bias due to nonresponse). Samples of 110 PSUs were drawn for 2006–2010 and 117 PSUs were drawn for 2011–2015. Both PSU samples were divided into four fully representative national samples. Interviewing was done for 1 year in each subsample; the entire 110-PSU design was completed in the 4-year period, 2006–2010. The 2011–2013 file contained interviews from 65 PSUs, equal to 2 of the 4 subsamples drawn for the 2011– 2015 NSFG. The interviews were administered in person by trained female interviewers using a laptop or notebook computer with computer-assisted personal interviewing (CAPI) or audio computer-assisted self-interview (ACASI) programs.

In all survey years, black women were sampled at higher rates than white women so that more reliable statistics could be produced for black women. In both the 1995 and 2002 surveys, Hispanic persons were also oversampled. In the 2006–2010 and 2011–2013 NSFG, black and Hispanic adults and all 15- to 19-year-olds were oversampled.

To produce national estimates from the sample for the millions of women aged 15–44 in the United States, data for the interviewed sample women were (a) inflated by the reciprocal of the probability of selection at each stage of sampling (for example, if there was a 1 in 5,000 chance that a woman would be selected for the sample, her sampling weight was 5,000); (b) adjusted for nonresponse; and (c) poststratified, or aligned with benchmark population sizes based on data from the U.S. Census Bureau.

##### Sample Size and Response Rate

For the 1982, 1995, 2002, and 2006–2010 surveys, the response rate ranged from 78%–80%. The response for the 2011–2013 survey was 73%. Sample sizes have varied over the surveys: in 1982 the sample size was 7,969; in 1995 it was 10,847; in 2002 it was 7,643; in 2006–2010 it was 12,279; and in 2011–2013 it was 5,601.

###### References

Bachrach CA, Horn MC, Mosher WD, Shimizu I. National Survey of Family Growth, cycle III: Sample design, weighting, and variance estimation. NCHS. Vital Health Stat. 1985;2(98). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_098.pdf.
Judkins DR, Mosher WD, Botman S. National Survey of Family Growth: Design, estimation, and inference. NCHS. Vital Health Stat. 1991;2(109). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_109.pdf.
Kelly JE, Mosher WD, Duffer AP, Kinsey SH. Plan and operation of the 1995 National Survey of Family Growth. NCHS. Vital Health Stat. 1997;1(36). Available from: http://www.cdc.gov/nchs/data/series/sr_01/sr01_036.pdf.
Potter FJ, Iannacchione VG, Mosher WD, et al. Sample design, sampling weights, imputation, and variance estimation in the 1995 National Survey of Family Growth. NCHS. Vital Health Stat. 1998;2(124). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_124.pdf.
Groves RM, Benson G, Mosher WD, et al. Plan and operation of cycle 6 of the National Survey of Family Growth. NCHS. Vital Health Stat. 2005;1(42). Available from: http://www.cdc.gov/nchs/data/series/sr_01/sr01_042.pdf.
Groves RM, Mosher WD, Lepkowski J, Kirgis NG. Planning and development of the continuous National Survey of Family Growth. NCHS. Vital Health Stat. 2009;1(48). Available from: http://www.cdc.gov/nchs/data/series/sr_01/sr01_048.pdf.
Lepkowski JM, Mosher WD, Davis KE, et al. The 2006–2010 National Survey of Family Growth: Sample design and analysis of a continuous survey. NCHS. Vital Health Stat. 2010;2(150). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_150.pdf.
Lepkowski JM, Mosher WD, Groves RM, et al. Responsive design, weighting, and variance estimation in the 2006–2010 National Survey of Family Growth. NCHS. Vital Health Stat. 2013;2(158). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_158.pdf.

##### For More Information

See the NSFG website at: http://www.cdc.gov/nchs/nsfg.htm.

### National Survey on Drug Use & Health (NSDUH)

#### Substance Abuse and Mental Health Services Administration (SAMHSA)

##### Overview

NSDUH, formerly called the National Household Survey on Drug Abuse (NHSDA), collects data on substance use, abuse, and dependence; mental health problems; and receipt of substance abuse and mental health treatment. NSDUH reports on the prevalence, incidence, and patterns of drug and alcohol use and abuse in the general U.S. civilian noninstitutionalized population aged 12 and over. NSDUH also reports on substance use disorders, substance use treatment, health care, mental health disorders, and mental health service utilization.

##### Coverage

NSDUH is representative of persons aged 12 and over in the civilian noninstitutionalized population of the United States, and representative in each state and D.C. NSDUH oversamples youths and young adults.

The survey covers residents of households (including those living in houses, townhouses, apartments, and condominiums), persons in noninstitutional group quarters (including those in shelters, boarding houses, college dormitories, migratory work camps, and halfway houses), and civilians living on military bases. Persons excluded from the survey include homeless people who do not use shelters, active military personnel, and residents of institutional group quarters such as jails and hospitals.

##### Methodology

The data collection method is in-person interviews conducted with a sample of individuals at their place of residence. Computer-assisted interviewing (CAI) methods, including audio computer-assisted self-interviewing (ACASI), are used to provide a private and confidential setting to complete the interview.

NSDUH uses a 50-state sample design. In 2005, NSDUH introduced a coordinated 5-year sample design in which the first stage of selection involved census tracts, with sample segments within a single census tract to the extent possible. States were first stratified into a total of 900 state sampling regions (48 regions in each large sample state and 12 regions in each small sample state). These regions were contiguous geographic areas designed to yield the same number of interviews on average. Starting with the 2005 survey, a total of 48 census tracts per state sampling region were selected with probability proportional to size. Within sampled census tracts, adjacent census blocks were combined to form the second-stage sampling units, or area segments. Of these segments, 24 were designated for the coordinated 5-year sample and 24 were designated as reserve segments. Eight sample segments per state sampling region were fielded during the survey year. These sampled segments were allocated equally into four separate samples, one for each 3-month period (calendar quarter) during the year, so that the survey was essentially continuous in the field.

The design also oversampled youths and young adults, so that each state’s sample was approximately equally distributed among three major age groups: 12–17, 18–25, and 26 and over.

##### Sample Size and Response Rate

Nationally, 160,325 household addresses were successfully screened for the 2013 survey, conducted from January to December 2013. In these screened households, a total of 88,742 sample persons were selected, from which 67,838 completed interviews were obtained. Weighted response rates were 84% for household screening and 72% for interviewing.

##### Issues Affecting Interpretation

Several improvements to the survey were implemented in 2002, when the survey was redesigned as NSDUH. In addition to the name change, respondents were offered a $30 incentive payment for participation in the survey starting in 2002, and quality control procedures for data collection were enhanced in 2001 and 2002. Because of these improvements and modifications, estimates from NSDUH completed in 2002 and later should not be compared with estimates from the 2001 or earlier versions of the survey. The data collected in 2002 represent a new baseline for tracking trends in substance use and other measures. Special questions on methamphetamine were added in 2005 and 2006. Data for years prior to 2007 were adjusted for comparability. Starting with 2011 data, 2010-census based control totals were used in the weighting process. For the analysis weights in the 2002 through 2010 NSDUHs, the weights were derived from the 2000 census data. This reweighting to the 2010 census data could affect comparisons between estimates for 2011 and subsequent years and those from prior years. An analysis of the impact of reweighting showed that the percentages of substance users were largely unaffected.

For more information, see: http://www.samhsa.gov/data/NSDUH/NSDUHCensusEffects/Index.aspx.

Estimates of substance use for youth based on NSDUH are not directly comparable with estimates based on the Monitoring the Future (MTF) Study and the Youth Risk Behavior Survey (YRBS). In addition to the fact that MTF excludes dropouts and absentees, rates are not directly comparable across these surveys because of differences in the populations covered, sample design, questionnaires, and interview setting. NSDUH collects data in residences, whereas MTF and YRBS collect data in school classrooms. Further, NSDUH estimates are tabulated by age, whereas MTF and YRBS estimates are tabulated by grade, representing different ages as well as different populations.

###### Reference

Substance Abuse and Mental Health Services Administration. Results from the 2013 National Survey on Drug Use and Health: Summary of national findings. NSDUH series H–48. HHS pub no (SMA) 143–4863. Rockville, MD. SAMHSA. 2014. Available from: http://archive.samhsa.gov/data/NSDUH/2013SummNatFindDetTables/NationalFindings/NSDUHresults2013.htm.

##### For More Information

See the NSDUH website at: http://www.samhsa.gov/data/population-data-nsduh and the Center for Behavioral Health Statistics and Quality (the data collection agency) website at: http://www.samhsa.gov/about-us/who-we-are/offices-centers/cbhsq.

### National Vital Statistics System (NVSS)

#### CDC/NCHS

##### Overview

NVSS collects and publishes official national statistics on births, deaths, fetal deaths, and, prior to 1996, marriages and divorces occurring in the United States, based on U.S. Standard Certificates. Fetal deaths are classified and tabulated separately from other deaths. The vital statistics files—Birth, Fetal Death, Mortality Multiple Cause-of-Death, Linked Birth/Infant Death, and Compressed Mortality—are described in detail below.

##### Coverage

NVSS collects and presents U.S. resident data for the aggregate of 50 states, New York City, and D.C., as well as for each individual state and D.C. and the U.S. dependent areas of Puerto Rico, Virgin Islands, Guam, American Samoa, and Northern Marianas. Vital events occurring in the United States to non-U.S. residents, and vital events occurring abroad to U.S. residents, are excluded. Starting with Health, United States, 2013, information on vital events for Puerto Rico, Virgin Islands, Guam, American Samoa, and Northern Marianas is shown in selected tables that show data by state, but are not included in U.S. totals.

##### Methodology

NCHS’ Division of Vital Statistics obtains information on births and deaths from the registration offices of each of the 50 states, New York City, D.C., Puerto Rico, Virgin Islands, Guam, American Samoa, and Northern Marianas. Until 1972, microfilm copies of all death certificates and a 50% sample of birth certificates were received from all registration areas and processed by NCHS. In 1972, some states began sending their data to NCHS through the Cooperative Health Statistics System (CHSS). States that participated in the CHSS program processed 100% of their death and birth records and sent the entire data file to NCHS on computer tapes. Currently, data are sent to NCHS through the Vital Statistics Cooperative Program (VSCP), following the same procedures as with CHSS. The number of participating states grew from 6 in 1972 to 46 in 1984. Starting in 1985, all 50 states and D.C. participated in VSCP.

##### U.S. Standard Certificates

U.S. Standard Certificates of Live Birth and Death and Fetal Death Reports are revised periodically, allowing evaluation and addition, modification, and deletion of items. Beginning with 1989, revised Standard Certificates replaced the 1978 versions. The 1989 revision of the birth certificate included items to identify the Hispanic parentage of newborns and to expand information about maternal and infant health characteristics. The 1989 revision of the death certificate included items on educational attainment and Hispanic origin of decedents, as well as changes to improve the medical certification of cause of death. Standard Certificates recommended by NCHS are modified in each registration area to serve the area’s needs. However, most certificates conform closely in content and arrangement to the Standard Certificate, and all certificates contain a minimum data set specified by NCHS. The 2003 revision of vital records went into effect in some states and territories beginning in 2003, but full implementation in all states and territories will be phased in over several years. The 2003 revision of the birth certificate included changes in ascertainment of education level, prenatal care, and tobacco use during pregnancy. The 2003 revision of the death certificate included changes in the ascertainment of multiple races, education level, tobacco use, and maternal mortality.

#### Birth File

##### Overview

Vital statistics natality data are a fundamental source of demographic, geographic, and medical and health information on all births occurring in the United States. This is one of the few sources of comparable health-related data for small geographic areas over an extended time period. The data are used to present the characteristics of babies and their mothers, track trends such as birth rates for teenagers, and compare natality trends with those in other countries.

The Birth file includes characteristics of the baby, such as sex, birthweight, and weeks of gestation; demographic information about the parents, such as age, race, Hispanic origin, parity, educational attainment, marital status, and state of residence; medical and health information, such as prenatal care, based on hospital records; and behavioral risk factors for the birth, such as mother’s tobacco use during pregnancy.

##### Coverage

Birth data presented in Health, United States are based on reporting from all 50 states and D.C. Data for Puerto Rico, Virgin Islands, Guam, American Samoa, and Northern Marianas are shown in selected state tables but are not included in U.S. totals. Beginning with 1970, births to nonresidents of the United States are excluded.

##### Methodology

In the United States, state laws require birth certificates to be completed for all births. The registration of births is the responsibility of the professional attendant at birth, generally a physician or midwife. The birth certificate must be filed with the local registrar of the district in which the birth occurs. Each birth must be reported promptly; the reporting requirements vary from state to state, ranging from 24 hours to as much as 10 days after the birth.

Federal law mandates national collection and publication of birth and other vital statistics data. NVSS is the result of cooperation between NCHS and the states to provide access to statistical information from birth certificates. Standard forms for the collection of the data, and model procedures for the uniform registration of the events, are developed and recommended for state use through cooperative activities of the states and NCHS. NCHS shares the costs incurred by the states in providing vital statistics data for national use.

##### Issues Affecting Interpretation

Two-thirds (66%) of all births in 2009, 76% in 2010, 83% in 2011, 86% in 2012, and 90% in 2013 reported using the 2003 revision of the U.S. Standard Certificate of Live Birth. Interpretation of trend data should take into consideration changes to reporting areas. For methodological and reporting area changes for the following birth certificate items, see Appendix II, Age; Hispanic origin; Marital status; Race.

###### Reference

Martin JA, Hamilton BE, Osterman MJK, et al. Births: Final data for 2013. National vital statistics reports. Hyattsville, MD. NCHS. 2015;64(1). Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr64/nvsr64_01.pdf.

##### For More Information

See the Birth Data website at: http://www.cdc.gov/nchs/births.htm, and Vitalstats at: http://www.cdc.gov/nchs/data_access/Vitalstatsonline.htm.

#### Fetal Death Data Set

##### Overview

Fetal mortality refers to the intrauterine death of a fetus at any gestational age. In Health, United States, data are presented for fetal deaths at 20 weeks or more. The Fetal Death data set includes characteristics of the fetus, such as sex, birthweight, and weeks of gestation; demographic information about the mother, such as age, race, Hispanic origin, live-birth order, and marital status; and medical and health information, such as maternal diabetes and hypertension.

##### Coverage

Data presented in Health, United States are based on reporting from all 50 states and D.C. Data for Puerto Rico, Virgin Islands, Guam, American Samoa, and Northern Marianas are not included in U.S. totals but are included in the Fetal Death User Guide available from the NCHS website at: http://www.cdc.gov/nchs/data_access/VitalStatsOnline.htm, and in periodic reports.

##### Methodology

Fetal death means the death of a fetus prior to delivery from the mother, irrespective of the duration of pregnancy. Fetal deaths do not include induced terminations of pregnancy. This definition of fetal death, adopted by NCHS as the nationally recommended standard, is based on the definition published by the World Health Organization in 1950 and revised in 1988. The term fetal death encompasses other commonly used terms, including stillbirth, spontaneous abortion, and miscarriage. All U.S. states and registration areas have definitions similar to the standard definition, except for Puerto Rico and Wisconsin, which have no formal definition.

State laws require the reporting of fetal deaths, and federal law mandates national collection and publication of fetal death data. States and reporting areas submit fetal mortality data to NCHS as part of a cooperative agreement. Standard forms and procedures for the collection of the data are developed and recommended for state use through cooperative activities of the states and NCHS. NCHS shares the costs incurred by the states in providing vital statistics data for national use.

In addition to fetal mortality rates, perinatal mortality rates are also presented in Health, United States. Perinatal mortality includes both late fetal deaths (of at least 28 weeks of gestation) and early infant (neonatal) deaths (within 7 days of birth). Data on early infant deaths come from the Linked Birth/Infant Death data set.

##### Issues Affecting Interpretation

Reporting requirements for fetal deaths vary by state, and these differences have important implications for comparisons of fetal mortality rates by state. The majority of states require reporting of fetal deaths at 20 weeks of gestation or more, or a minimum of 350 grams birthweight (roughly equivalent to 20 weeks), or some combination of the two. However, seven states require reporting of fetal deaths at all periods of gestation, and one state requires reporting beginning at 16 weeks of gestation. Further, two states require the reporting of fetal deaths with birthweights of 500 grams or more (roughly equivalent to 22 weeks of gestation).

There is substantial evidence that not all fetal deaths for which reporting is required are, in fact, reported. Underreporting of fetal deaths is most likely to occur in the earlier part of the required reporting period for each state. For example, in 2006, for states that required the reporting of fetal deaths at all periods of gestation, 58% of fetal deaths at 20 weeks or more gestation occurred within 20–27 weeks, whereas for states that required reporting of fetal deaths at 500 grams or more, only 28% were within 20–27 weeks. This disparity suggests substantial underreporting of early fetal deaths in some states.

###### References

MacDorman MF, Kirmeyer SE, Wilson EC. Fetal and perinatal mortality, United States, 2006. National vital statistics report. Hyattsville, MD. NCHS. 2012;60(8). Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr60/nvsr60_08.pdf.
Gregory ECW, MacDorman MF, Martin JA. Trends in fetal and perinatal mortality in the United States, 2006–2012. NCHS data brief, no 169. Hyattsville, MD. NCHS. 2014. Available from: http://www.cdc.gov/nchs/data/databriefs/db169.htm.

##### For More Information

See the NCHS Fetal Deaths data website at: http://www.cdc.gov/nchs/fetal_death.htm.

#### Mortality Multiple Cause-of-Death File

##### Overview

Vital statistics mortality data are a fundamental source of demographic, geographic, and underlying and multiple cause-of-death information. Multiple cause-of-death data reflect all medical information reported on death certificates and complement traditional underlying cause-of-death data. Multiple-cause data give information on diseases that are a factor in death, whether or not they are the underlying cause of death; on associations among diseases; and on injuries leading to death.

The Mortality multiple cause-of-death file includes demographic information on age, sex, race, Hispanic origin, state of residence, and educational attainment, as well as medical information on causes of death. This data set is one of the few sources of comparable health-related data for small geographic areas over an extended time period. The data are used to present the characteristics of those dying in the United States, to determine life expectancy, and to compare mortality trends with those in other countries.

##### Coverage

Mortality data presented in Health, United States are based on reporting from all 50 states and D.C. Data for Puerto Rico, Virgin Islands, Guam, American Samoa, and Northern Marianas are shown in selected state tables, but are not included in U.S. totals. Beginning with 1970, mortality statistics for the U.S. exclude deaths of nonresidents of the U.S. Mortality statistics for Puerto Rico, Virgin Islands, American Samoa, and Northern Marianas excluded deaths of nonresidents for each area. For Guam, mortality statistics exclude deaths that occurred to a resident of any place other than Guam or the U.S. (50 states and D.C.).

##### Methodology

By law, the registration of deaths is the responsibility of the funeral director. The funeral director obtains demographic data for the death certificate from an informant. The physician in attendance at the death is required to certify the cause of death. Where death is from other than natural causes, a coroner or medical examiner may be required to examine the body and certify the cause of death.

NCHS is responsible for compiling and publishing annual national statistics on causes of death. In carrying out this responsibility, NCHS adheres to the World Health Organization (WHO) Nomenclature Regulations. These regulations require (a) that cause of death be coded in accordance with the applicable revision of the International Classification of Diseases (ICD) (see Appendix II, International Classification of Diseases [ICD]; Table III); and (b) that underlying cause of death be selected in accordance with international rules. Traditionally, national mortality statistics have been based on a count of deaths, with one underlying cause assigned for each death.

Prior to 1968, mortality medical data were based on manual coding of an underlying cause of death for each certificate, in accordance with WHO rules. Starting with 1968, NCHS converted to computerized coding of the underlying cause and manual coding of all causes (multiple causes) on the death certificate. In this system, called Automated Classification of Medical Entities (ACME), multiple-cause codes serve as inputs to the computer software, which employs WHO rules to select the underlying cause. ACME is used to select the underlying cause of death for all death certificates in the United States, and cause-of-death data in Health, United States are coded using ACME.

In addition, NCHS has developed two computer systems as inputs to ACME. Beginning with 1990 data, the Mortality Medical Indexing, Classification, and Retrieval system (MICAR) was introduced to automate coding of multiple causes of death. MICAR provides more detailed information on the conditions reported on death certificates than is available through the ICD code structure. Then, beginning with data year 1993, SuperMICAR, an enhancement of MICAR, was introduced. SuperMICAR allows for literal entry of the multiple cause-of-death text as reported by the certifier. This information is then processed automatically by the MICAR and ACME computer systems. Records that cannot be processed automatically by MICAR or SuperMICAR are multiple-cause-coded manually and then further processed through ACME. Starting in 2003, SuperMICAR was used to process all of the nation’s death records.

Data for the entire United States refer to events occurring within the United States; data for geographic areas are by place of residence. For methodological and reporting area changes for the following death certificate items, see Appendix II, Hispanic origin; Race.

##### Issues Affecting Interpretation

The International Classification of Diseases (ICD), by which cause of death is coded and classified, is revised approximately every 10–20 years. Because revisions of the ICD may cause discontinuities in trend data by cause of death, comparison of death rates by cause of death across ICD revisions should be done with caution and with reference to the comparability ratio. (See Appendix II, Comparability ratio.) Prior to 1999, modifications to the ICD were made only when a new revision of the ICD was implemented. A process for updating the ICD was introduced with the 10th revision (ICD–10) that allows for midrevision changes. These changes, however, may affect comparability of data between years for select causes of death. Minor changes may be implemented every year, whereas major changes may be implemented every 3 years (e.g., 2003 data year). In data year 2006, major changes were implemented, including the addition and deletion of several ICD codes. For more information, see Heron et al. (2009).

Multiple-cause data were obtained from all certificates for 1968–1971, 1973–1980, and 1983–present. Data were obtained from a 50% sample of certificates for 1972. Multiple-cause data for 1981 and 1982 were obtained from a 50% sample of certificates from 19 registration areas. For the other states, data were obtained from all certificates.

The death certificate has been revised periodically. A revised U.S. Standard Certificate of Death was recommended for state use beginning January 1, 1989. Among the changes were the addition of a new item on educational attainment and Hispanic origin of the decedent and changes to improve the medical certification of cause of death. The U.S. Standard Certificate of Death was revised again in 2003; states are adopting this new certificate on a rolling basis.

The 2003 revision permits reporting of more than one race (multiple races). This change was implemented to reflect the increasing diversity of the U.S. population and to be consistent with the decennial census. Some states, however, are still using the 1989 revision of the U.S. Standard Certificate of Death, which allows only a single race to be reported. Until all states adopt the new death certificate, the race data reported using the 2003 revision are “bridged” for those for whom more than one race was reported (multiple race) to one single race, to provide comparability with race data reported on the 1989 revision. For more information on the impact of the 2003 certificate revisions on mortality data presented in Health, United States, see Appendix II, Race.

###### References

Xu JQ, Murphy SL, Kochanek KD, et al. Deaths: Final data for 2013. National vital statistics reports. Hyattsville, MD. NCHS. 2015;64(2). [Forthcoming]. Portions available from: http://www.cdc.gov/nchs/data/nvsr/nvsr64/nvsr64_02.pdf.
Murphy SL, Kochanek KD, Xu JQ, et al. Deaths: Final data for 2012. National vital statistics reports. Hyattsville, MD. NCHS. 2014;63(9). Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr63/nvsr63_09.pdf.
Kochanek KD, Murphy SL, Xu JQ, et al. Deaths: Final data for 2011. National vital statistics reports. Hyattsville, MD. NCHS. 2014;63(3). Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr63/nvsr63_03.pdf.
Heron M, Hoyert DL, Murphy SL, et al. Deaths: Final data for 2006. National vital statistics reports. Hyattsville, MD. NCHS. 2009;57(14). Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr57/nvsr57_14.pdf.
NCHS. Multiple causes of death in the United States. Monthly vital statistics report. Hyattsville, MD. NCHS. 1984;32(10 suppl 2). Available from: http://www.cdc.gov/nchs/data/mvsr/supp/mv32_10s2.pdf.

##### For More Information

See the Mortality Data website at: http://www.cdc.gov/nchs/deaths.htm.

#### Linked Birth/Infant Death Data Set

##### Overview

National linked files of live births and infant deaths are used for research on infant mortality. The Linked Birth/Infant Death data set links information from the birth certificate to information from the death certificate for each infant death in the United States. The purpose of the linkage is to use the many additional variables from the birth certificate, including the more accurate race and ethnicity data, for more detailed analyses of infant mortality patterns. The Linked Birth/Infant Death data set includes all variables on the natality (Birth) file, including racial and ethnic information, birthweight, and maternal smoking, as well as variables on the Mortality file, including cause of death and age at death.

##### Coverage

To be included in the U.S. linked file, both the birth and death must have occurred in the 50 states, D.C., Puerto Rico, Virgin Islands, or Guam. Data for Puerto Rico, Virgin Islands, and Guam are shown in selected state tables but are not included in U.S. totals. Linked birth/infant death data are not available for American Samoa and Northern Marianas.

##### Methodology

Infant deaths are defined as a death before the infant’s first birthday. About 98%–99% of infant death records can be linked to their corresponding birth certificates. The linkage makes available extensive information from the birth certificate about the pregnancy, maternal risk factors, infant characteristics, and health items at birth that can be used for more detailed analyses of infant mortality. The linked file is used for calculating infant mortality rates by race and ethnicity, which are more accurately measured from the birth certificate.

Starting with 1995 data, linked birth/infant death data files are available in two different formats: period data and birth cohort data. The numerator for the period linked file consists of all infant deaths occurring in a given data year linked to their corresponding birth certificates, whether the birth occurred in that year or the previous year. The numerator for the birth cohort linked file consists of deaths to infants born in a given year. In both cases, the denominator is all births occurring in the year. For example, the 2012 period linked file contains a numerator file that consists of all infant deaths occurring in 2012 that have been linked to their corresponding birth certificates, whether the birth occurred in 2011 or 2012. In contrast, the 2012 birth cohort linked file will contain a numerator file that consists of all infant deaths to babies born in 2012, whether the death occurred in 2012 or 2013. Although the birth cohort format has methodological advantages, it creates substantial delays in data availability because it is necessary to wait until the close of the following data year to include all infant deaths in the birth cohort. Starting with 1995 data, period linked files are used for infant mortality rate tables in Health, United States.

Other changes to the data set starting with 1995 include the addition of record weights to compensate for the 1%–2% of infant death records that could not be linked to their corresponding birth records. In addition, not-stated birthweight was imputed if the period of gestation was known. This imputation was done to improve the accuracy of birthweight-specific infant mortality rates because the percentage of records with not-stated birthweight is generally higher for infant deaths (4.0% in 2012) than for live births (0.1% in 2012). In both 2011 and 2012, not-stated birthweight was imputed for 0.08% of births.

##### Issues Affecting Interpretation

Period linked file data starting with 1995 are not strictly comparable with birth cohort data for 1983–1991. A new revision of the birth certificate was introduced in 2003 and is being adopted by states on a voluntary, rolling basis.

###### References

NCHS. Public use data file documentation: 2012 period Linked Birth/Infant Death data set. Hyattsville, MD. NCHS. 2014. Available from: ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Dataset_Documentation/DVS/periodlinked/LinkPE12Guide.pdf.
Mathews TJ, MacDorman MF. Infant mortality statistics from the 2010 period Linked Birth/Infant Death data set. National vital statistics report. Hyattsville, MD. NCHS. 2013;62(8). Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr62/nvsr62_08.pdf.

##### For More Information

See the NCHS Linked Birth and Infant Death Data website at: http://www.cdc.gov/nchs/linked.htm.

#### Compressed Mortality File (CMF)

##### Overview

The CMF is a county-level national mortality and population database. It contains mortality data derived from the detailed Mortality multiple cause-of-death files of NVSS and estimates of U.S. national, state, and county resident populations from the U.S. Census Bureau. For 1968–1998, the number of deaths, crude death rates, and age-adjusted death rates can be obtained by place of residence (total U.S., state, and county), age group, race (white, black, and other), sex, year of death, and underlying cause of death. For 1999–2013, mortality statistics can be obtained by place of residence, age group, expanded race groups (white, black, American Indian or Alaska Native, Asian or Pacific Islander), Hispanic origin, sex, and year of death.

##### Methodology

In Health, United States, the CMF is used to compute death rates by urbanization level of the decedent’s county of residence. Counties can be categorized according to level of urbanization based on either 2006 or 2013 “NCHS Urban-Rural Classification Scheme for Counties” (available from: http://www.cdc.gov/nchs/data_access/urban_rural.htm).This scheme assigns counties and county equivalents to one of six urbanization levels: four metropolitan and two nonmetropolitan.

##### For More Information

See the CMF website at: http://www.cdc.gov/nchs/data_access/cmf.htm and the CDC WONDER website at: http://wonder.cdc.gov/. (Also see Appendix II, Urbanization.)

### Occupational Employment Statistics (OES)

#### Bureau of Labor Statistics (BLS)

##### Overview

The OES program conducts a semiannual survey designed to produce estimates of employment and wages for specific occupations. The program collects data on wage and salary workers in nonfarm establishments in order to produce employment and wage estimates for about 800 occupations. The OES program produces these occupational estimates for the nation as a whole, by state, by metropolitan or nonmetropolitan area, and by industry or ownership. BLS produces occupational employment and wage estimates for over 430 industry classifications at the national level.

##### Coverage

The OES survey covers all full-time and part-time wage and salary workers in nonfarm establishments. The survey does not cover the self-employed, owners and partners in unincorporated firms, household workers, or unpaid family workers.

##### Methodology

The OES program surveys approximately 200,000 establishments per panel (every 6 months), taking 3 years to fully collect the sample of 1.2 million establishments. The estimates for occupations in nonfarm establishments are based on OES data collected for the reference months of May and November. May 2013 employment and wage estimates are based on all data collected from establishments sampled in the May 2013, November 2012, May 2012, November 2011, May 2011, and November 2010 semiannual panels. The overall national response rate for the six panels is 75% based on establishments, covering 72% based on employment. The OES survey is a federal-state cooperative program between BLS and state workforce agencies (SWAs). BLS provides the procedures and technical support, draws the sample, and produces the survey materials, while SWAs collect most of the data. SWAs from all 50 states plus D.C., Puerto Rico, Guam, and the U.S. Virgin Islands participate in the survey. Occupational employment and wage rate estimates at the national level are produced by BLS using data from the 50 states and D.C. Employers who respond to states’ requests to participate in the OES survey make these estimates possible.

##### Issues Affecting Interpretation

Because of revisions to the occupational classification system, more recent OES estimates may not be directly comparable with data from previous years.

The May 2013 and May 2012 OES estimates are based on the Office of Management and Budget’s revised 2010 Standard Occupational Classification (SOC) system. The OES survey classifies workers into 821 detailed occupations based on the 2010 SOC. Together, these detailed occupations make up 22 of the 23 SOC major groups. Major group 55, Military Specific Occupations, is not included. The May 2013 and May 2012 estimates also include national data for SOC minor groups and broad occupations.

OES estimates for 2010 and 2011 were based on a hybrid structure of the 2000 and 2010 SOC systems. For more information about the hybrid structure, see FAQ 8 at http://www.bls.gov/oes/oes_ques.htm#other. Estimates from 1999 through 2009 were based on the 2000 SOC.

The May 2013 and May 2012 OES data are based on the 2012 North American Industry Classification System (NAICS). Data from 2008 through 2011 are based on the 2007 NAICS, and data from 2002 through 2007 are based on the 2002 NAICS. Data prior to 2002 are based on the Standard Industrial Classification (SIC) system.

###### Reference

Bureau of Labor Statistics. Occupational employment and wages, May 2013. Washington, DC. U.S. Department of Labor. 2014. Available from: http://www.bls.gov/oes/home.htm.

##### For More Information

See the OES website at: http://www.bls.gov/OES.

### Population Census and Population Estimates

#### U.S. Census Bureau

#### Decennial Census

The census of population (decennial census) has been held in the United States every 10 years since 1790. Since 1930, it has enumerated the resident population as of April 1 of the census year. Data on sex, race, Hispanic origin, age, and marital status are collected from 100% of the enumerated population.

#### Race Data on the 1990 Census

The question on race on the 1990 census was based on the Office of Management and Budget’s (OMB) 1977 Race and Ethnic Standards for Federal Statistics and Administrative Reporting (Statistical Policy Directive 15). This document specified rules for the collection, tabulation, and reporting of race and ethnicity data within the federal statistical system. The 1977 Standards required federal agencies to report race-specific tabulations using four single-race categories: American Indian or Alaska Native, Asian or Pacific Islander, black, and white. Under the 1977 Standards, race and ethnicity were considered to be two separate and distinct concepts. Thus, persons of Hispanic origin may be of any race.

#### Race Data on the 2000 Census

The question on race on the 2000 census was based on OMB’s 1997 Revisions to the Standards for the Classification of Federal Data on Race and Ethnicity (Fed Regist 1997 October 30;62:58781–90). (Also see Appendix II, Race.) The 1997 Standards incorporated two major changes in the collection, tabulation, and presentation of race data. First, the 1997 Standards increased from four to five the minimum set of categories to be used by federal agencies for identification of race: American Indian or Alaska Native, Asian, black or African American, Native Hawaiian or Other Pacific Islander, and white. Second, the 1997 Standards included the requirement that federal data collection programs allow respondents to select one or more race categories when responding to a query on their racial identity. This provision means that there are potentially 31 race groups, depending on whether an individual selects one, two, three, four, or all five of the race categories. The 1997 Standards continue to call for use, when possible, of a separate question on Hispanic or Latino ethnicity and specify that the ethnicity question should appear before the question on race. Thus, under the 1997 Standards, as under the 1977 Standards, persons of Hispanic origin may be of any race.

#### Race Data on the 2010 Census

Similar to race data on the 2000 census, the question on race on the 2010 census was based on OMB’s 1997 Revisions to the Standards for the Classification of Federal Data on Race and Ethnicity (Fed Regist 1997 October 30;62:58781–90). (Also see Appendix II, Race.) The 1997 Standards required a minimum set of categories to be used by federal agencies for identification of race: American Indian or Alaska Native, Asian, black or African American, Native Hawaiian or Other Pacific Islander, and white and require that federal data collection programs allow respondents to select one or more race categories when responding to a query on their racial identity. The 1997 Standards continue to call for use, when possible, of a separate question on Hispanic or Latino ethnicity and specify that the ethnicity question should appear before the question on race. Thus, under the 1997 Standards, as under the 1977 Standards, persons of Hispanic origin may be of any race.

#### Modified Decennial Census Files

For several decades the U.S. Census Bureau has produced Modified Decennial Census files. These modified files incorporate adjustments to the 100% April 1 count data for (a) errors in the census data discovered subsequent to publication, (b) misreported age data, and (c) nonspecified race.

For the 1990 census, the U.S. Census Bureau modified the age, race, and sex data on the census and produced the Modified Age-Race-Sex (MARS) file. The differences between the population counts in the original census file and the MARS file are primarily due to modification of the race data. Of the 248.7 million persons enumerated in 1990, 9.8 million did not specify their race (over 95% were of Hispanic origin). For the 1990 MARS file, these persons were assigned the race reported by a nearby person with an identical response to the Hispanic origin question.

For the 2000 and 2010 censuses, the U.S. Census Bureau modified the race data and produced the Modified Race Data Summary files. For these files, persons who did not report a race (reported only the category Some Other Race) as part of their race response were assigned by imputation to one of the 31 race groups, which are the single- and multiple-race combinations of the five race categories specified in the 1997 OMB race and ethnicity standards. For the 2000 census, 97% of the 15.4 million persons who did not report a race were of Hispanic origin. Because a large proportion of those identifying their race as Some Other Race are Hispanic, for the 2010 census, a new instruction was added that, for the census, Hispanic origins are not races. For the 2010 census, 97% of the 19.1 million persons who did not report a race (reported only the category Some Other Race) were of Hispanic origin.

#### Postcensal Population Estimates

Postcensal population estimates are estimates made for the years following a census, before the next census has been taken. Postcensal population estimates are derived annually by updating the resident population enumerated in the decennial census using a components-of-population-change approach. Each annual series includes estimates for the current data year and revised estimates for the earlier years in the decade. The following formula is used to derive national estimates for a given year from those for the previous year, starting with the decennial census enumerated resident population as the base:

Resident population estimate + births to U.S. resident women − deaths to U.S. residents + net international migration.

The postcensal estimates are consistent with official decennial census figures and do not reflect estimated decennial census underenumeration.

Estimates for the earlier years in a given series are revised to reflect changes in the components-of-change data sets (for example, births to U.S. resident women from a preliminary natality file are replaced with counts from a final natality file). To help users keep track of which postcensal estimate is being used, each annual series is referred to as a “vintage,” and the last year in the series is used to name the series. For example, both the Vintage 2001 and the Vintage 2002 postcensal series have revised estimates for July 1, 2001, but the estimates for July 1, 2001, from the Vintage 2001 and Vintage 2002 postcensal series differ.

The U.S. Census Bureau also produces postcensal estimates of the resident population of states and counties, using the components-of-population-change method. An additional component of population change—net internal migration—is involved.

#### Intercensal Population Estimates

Intercensal population estimates are estimates made for the years between two decennial censuses and are produced once the census at the end of the decade has been completed. They replace the postcensal estimates produced prior to the completion of the census at the end of the decade. Intercensal estimates are more accurate than postcensal estimates because they are based on both the census at the beginning and the census at the end of the decade. They are derived by adjusting the final postcensal estimates for the decade to correct for the error of closure (the difference between the estimated population at the end of the decade and the census count for that date). The patterns of population change observed over the decade are preserved. The intercensal estimates for the 1990s were produced using the same methodology used to generate the intercensal estimates for the 1980s. The revised intercensal population estimates for 2000–2009 were produced using a modified version of the methodology used previously. Vital rates calculated using postcensal population estimates are routinely revised when intercensal estimates become available.

#### Bridged-race Population Estimates

Race data on the 2000 and 2010 censuses are not comparable with race data on other data systems that are continuing to collect data using the 1977 OMB Standards on race and ethnicity during the transition to full implementation of the 1997 OMB Standards. For example, states are implementing the revised birth and death certificates—which have race and ethnicity items that are compliant with the 1997 OMB Standards—at different times, and to date some states are still using the 1989 certificates that collect race and ethnicity data in accordance with the 1977 OMB Standards. Thus, population estimates for 1990 and beyond with race categories comparable with the 1977 OMB categories are needed so that race-specific birth and death rates can be calculated. To meet this need, NCHS, in collaboration with the U.S. Census Bureau, developed methodology to bridge the 31 race groups in Census 2000 and Census 2010 to the four single-race categories specified under the 1977 OMB Standards.

The bridging methodology was developed using information from the 1997–2000 National Health Interview Survey (NHIS). NHIS provides a unique opportunity to investigate multiple-race groups because, since 1982, it has allowed respondents to choose more than one race but has also asked respondents reporting multiple races to choose a primary race. The bridging methodology developed by NCHS involved the application of regression models relating person-level and county-level covariates to the selection of a particular primary race by the multiple-race respondents. The bridging proportions derived from these models have been applied by the U.S. Census Bureau to various unbridged resident population files. These applications have resulted in bridged-race population estimates for each of the four single-race categories: American Indian or Alaska Native, Asian or Pacific Islander, black, and white.

In Health, United States, vital rates for 1991–1999 were calculated using the July 1, 1991–July 1, 1999 bridged-race intercensal estimates. Vital rates for 2000 were calculated using the bridged-race April 1, 2000, census counts, and those for 2010 were calculated using the bridged-race April 1, 2010, census counts. Starting with Health, United States, 2012, vital rates for 2001–2009 have been recalculated using the July 1, 2001–July 1, 2009, revised intercensal bridged-race population estimates. Vital rates for 2011 and beyond will be calculated using bridged-race estimates of the July 1 population from the corresponding postcensal vintage.

##### Reference

Ingram DD, Parker JD, Schenker N, et al. United States Census 2000 population with bridged race categories. NCHS. Vital Health Stat. 2003;2(135). Available from: http://www.cdc.gov/nchs/data/series/sr_02/sr02_135.pdf.

#### For More Information

See the U.S. Census Bureau website at: http://www.census.gov and the NCHS website for U.S. Census populations with bridged race categories at: http://www.cdc.gov/nchs/nvss/bridged_race.htm.

### Quality Improvement Evaluation System (QIES)

#### Centers for Medicare & Medicaid Services (CMS)

##### Overview

This administrative database, referred to in Health, United States as QIES, is created from the Certification and Survey Provider Enhanced Reporting (CASPER) and QIES systems. QIES is a CMS database that contains information from the standard annual facility survey data submitted by state survey agencies to CMS for certification to participate in the Medicare and Medicaid programs in the United States and territories. (Data for the territories are not shown in Health, United States.) The purpose of the facility survey certification process is to ensure that facilities meet the current CMS care requirements and thus can be paid for services furnished to Medicare and Medicaid beneficiaries. In 2012, the QIES system replaced the Online Survey Certification and Reporting Database (OSCAR). QIES (and its predecessor OSCAR) contains information on facility and patient characteristics and health deficiencies issued by the government during the survey process.

##### Coverage

Facilities in the United States that are certified to receive Medicare or Medicaid payments are included.

##### Methodology

QIES data are compiled by the state survey agency and a facility representative. The data are reviewed during the survey process and then submitted electronically to CMS. The information provided can be audited at any time.

All certified facilities are inspected periodically by representatives of the state survey agency (generally the department of health). Some facilities are inspected twice, or more often, during any given reporting cycle. To avoid overcounting, the data must be edited and duplicates removed. Data editing and compilation of nursing home data were performed by Cowles Research Group (CRG; Anacortes, WA) and published in the group’s Nursing Home Statistical Yearbook series.

###### References

Cowles CM, editor. Nursing home statistical yearbooks for 2003–2013. Anacortes, WA. CRG. published 2004–2014 respectively.
Centers for Medicare & Medicaid Services. Certification and compliance. Baltimore, MD. CMS. 2005. Available from: http://www.cms.gov/CertificationandComplianc/01_Overview.asp.

##### For More Information

See the CMS website at: http://www.cms.hhs.gov/NonIdentifiableDataFiles and the CRG website at: http://www.longtermcareinfo.com/index.html.

### Sexually Transmitted Disease (STD) Surveillance

#### CDC/National Center for HIV/AIDS, Viral Hepatitis, STD, and TB Prevention (NCHHSTP)

##### Overview

Surveillance information on the incidence and prevalence of STDs is used to inform public and private health efforts to control these diseases. Case reporting data are available for nationally notifiable chancroid, chlamydia, gonorrhea, and syphilis. Surveillance of other STDs, such as genital herpes simplex virus, genital warts or other human papillomavirus infections, and trichomoniasis, are based on estimates of office visits in physician office practices provided by the National Disease and Therapeutic Index.

##### Coverage

Case reports of STDs are reported to CDC by STD surveillance systems operated by state and local STD control programs and health departments in 50 states, D.C., selected cities, 3,142 U.S. counties, and outlying areas consisting of U.S. dependencies, possessions, and independent nations in free association with the United States. Data from outlying areas are not included in Health, United States.

##### Methodology

Information is obtained from the following data sources: (a) notifiable disease reporting from state and local STD programs; (b) projects that monitor STD positivity and prevalence in various settings, including the National Job Training Program, the STD Surveillance Network, and the Gonococcal Isolate Surveillance Project; and (c) national sample surveys implemented by federal and private organizations. STD data are submitted to CDC on a variety of hard-copy summary reporting forms (monthly, quarterly, and annually) and in electronic summary or individual case-specific (line-listed) formats through the National Electronic Telecommunications System for Surveillance.

##### Issues Affecting Interpretation

Because of incomplete diagnosis and reporting, the number of STD cases reported to CDC undercounts the actual number of cases occurring among the U.S. population.

###### Reference

CDC. Sexually transmitted disease surveillance 2012. Atlanta, GA. CDC. 2014. Available from: http://www.cdc.gov/std/stats12/default.htm.

##### For More Information

See the STD Data and Statistics website at: http://www.cdc.gov/std/stats and the STD Diseases & Related Conditions website at: http://www.cdc.gov/std/default.htm.

### Surveillance, Epidemiology, and End Results Program (SEER)

#### National Cancer Institute (NCI)

##### Overview

SEER tracks the incidence of new cancers each year and collects follow-up information on all previously diagnosed patients until their death. For each cancer, SEER registries routinely collect data on patient demographics, primary tumor site, morphology, stage at diagnosis, first course of treatment, and follow-up for vital status.

##### Coverage

The SEER 9 registries (Atlanta, Connecticut, Detroit, Hawaii, Iowa, New Mexico, San Francisco-Oakland, Seattle-Puget Sound, and Utah) have been part of the program continuously since 1975. The SEER 13 registries (the SEER 9 registries plus Los Angeles, San Jose-Monterey, rural Georgia, and the Alaska Native Tumor Registry) have been part of the program continuously since 1992. The SEER 18 registries (the SEER 13 plus Greater Georgia, Kentucky, Greater California, New Jersey, and Louisiana) have been part of the program continuously since 2000. SEER currently collects and publishes cancer incidence and survival data from 18 population-based cancer registries covering approximately 28% of the U.S. population.

##### Methodology

A cancer registry collects and stores data on cancers diagnosed in a specific hospital or medical facility (hospital-based registry) or in a defined geographic area (population-based registry). A population-based registry includes, but is not limited to, a number of hospital-based registries. In SEER registry areas, trained coders abstract medical records using the International Classification of Diseases for Oncology, 3rd edition (ICD–O–3) to classify site and tumor morphology. The ICD–O–3 coding also includes updates for hematopoietic codes based on WHO Classification of Tumours of Haematopoietic and Lymphoid Tissues (2008). All SEER data in this report were collected with or converted to ICD–O–3.

NCI obtains population counts from the U.S. Census Bureau and uses them to calculate incidence rates. It also uses estimation procedures as needed to obtain estimates for years and races not included in data provided by the Census Bureau. Life tables used to determine general population life expectancy when calculating relative survival rates were obtained from NCHS and in-house calculations. Separate life tables are used for each race-sex-specific group included in SEER.

##### Issues Affecting Interpretation

Because of the addition of registries over time, analysis of long-term incidence and survival trends is limited to those registries that have been in SEER for similar lengths of time. Analysis of Hispanic and American Indian and Alaska Native data is limited to shorter trends. Starting with Health, United States, 2006, the North American Association of Central Cancer Registries (NAACCR) Hispanic Identification Algorithm was used on a combination of variables to classify cases as Hispanic for analytic purposes. Starting with Health, United States, 2007, Hispanic incidence data exclude data for Alaska. Earlier editions of Health, United States also excluded Hispanic data for Hawaii and Seattle. Starting with Health, United States, 2007, incidence estimates for the American Indian or Alaska Native population are limited to contract health service delivery area (CHSDA) counties within SEER reporting areas. This change is believed to produce estimates that more accurately reflect the incidence rates for this population group. More information on CHSDA is available from: http://www.ihs.gov/chs/index.cfm?module=chs_requirements_chsda. For more information on SEER estimates by race and ethnicity, see: http://seer.cancer.gov/seerstat/variables/seer/race_ethnicity/index.html. Rates presented in this report may differ somewhat from those reported previously due to changes in population estimates and the addition and deletion of small numbers of incidence cases.

###### Reference

Howlader N, Noone AM, Krapcho M, Garshell J, Miller D, Altekruse SF, et al., editors. SEER Cancer Statistics Review, 1975–2011. National Cancer Institute. Bethesda, MD. (based on November 2013 SEER data submission, posted to the SEER web site, April 2014.) Available from: http://seer.cancer.gov/csr/1975_2011/.

##### For More Information

See the SEER website at: http://seer.cancer.gov.

### United States Renal Data System (USRDS)

#### National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK), in conjunction with the Centers for Medicare & Medicaid Services (CMS) and the Health Resources and Services Administration (HRSA)

##### Overview

USRDS is a national data system that collects, analyzes, and distributes information about end-stage renal disease (ESRD) in the United States. USRDS staff collaborate with staff from CMS, HRSA, the Organ Procurement and Transplantation Network (OPTN) under the auspices of HRSA, and the ESRD networks, sharing data sets and actively working to improve the accuracy of ESRD patient information. USRDS has five goals: (a) to characterize the ESRD population; (b) to describe the prevalence and incidence of ESRD, along with trends in mortality and disease rates; (c) to investigate relationships among patient demographics, treatment modalities, and morbidity; (d) to identify new areas for special renal studies and support investigator-initiated research; and (e) to provide data sets and samples of national data to support research by the Special Studies Centers.

USRDS maintains a stand-alone database with data on the diagnoses and demographic characteristics of ESRD patients, along with biochemical data, dialysis claims, and information on treatment and payer histories, hospitalization events, deaths, physician and supplier services, and providers.

##### Coverage

The primary source of ESRD identification is the ESRD Medical Evidence form that is used to register patients at the onset of ESRD and that must be submitted by dialysis or transplant providers within 45 days of initiation. The form establishes Medicare eligibility for individuals previously not Medicare beneficiaries, reclassifies previously eligible beneficiaries as ESRD patients, and provides demographic and diagnostic information on all new patients. The CMS, USRDS, and renal research communities rely on the form to ascertain patient demographics, primary diagnosis, comorbidities, and biochemical test results at the time of ESRD initiation. Since 1995, providers have been required to complete the form for all new ESRD patients (Medicare and non-Medicare eligible).

##### Methodology

Data for the USRDS database are compiled from existing data sources, including the CMS Renal Management Information System (REMIS), CMS claims data, facility survey data, CDC survey data (National Health and Nutrition Examination Survey [NHANES]), Standard Information Management System (SIMS), Medicare Evidence form (CMS–2728), ESRD Death Notification form (CMS–274 6), and OPTN transplant and wait-list data. The CMS data files are supplemented by CMS with enrollment, payer history, and other administrative data, to provide utilization and demographic information on ESRD patients.

Coverage rates are 100% of people treated for ESRD since May 1995 because the amended ESRD entitlement policy requires that a Medicare Evidence form be submitted for all ESRD patients, regardless of their insurance and eligibility status. However, the payment data for non-Medicare ESRD patients may be absent during the 30-month coordination period.

##### Issues Affecting Interpretation

Ascertainment of incident cases may be incomplete because the data are for persons receiving ESRD treatment as reported to CMS and do not include patients who die of ESRD before receiving treatment and those who are not reported to CMS. In 2014, the methodology was revised and all data were reestimated.

###### Reference

National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases. United States Renal Data System annual data report 2014: An overview of the epidemiology of kidney disease in the United States. Bethesda, MD. NIH. 2014. Available from: http://www.usrds.org/adr.aspx.

##### For More Information

See the USRDS website at: http://www.usrds.org.

### Youth Risk Behavior Survey (YRBS)

#### CDC/National Center for HIV, Hepatitis, STD, and TB Prevention (NCHHSTP)

##### Overview

YRBS monitors health risk behaviors among students in grades 9–12 that contribute to morbidity and mortality in both adolescence and adulthood. The six areas monitored are behaviors that contribute to unintentional injuries and violence; tobacco use; alcohol and other drug use; sexual behaviors that contribute to unintended pregnancy and sexually transmitted diseases (STDs), including human immunodeficiency virus (HIV) infection; unhealthy dietary behaviors; and physical inactivity. In addition, YRBS monitors the prevalence of obesity, asthma, and sleep behaviors.

##### Coverage

National data are representative of high school students in public and private schools in the United States.

##### Methodology

The national YRBS school-based surveys have been conducted biennially since 1991. A three-stage cluster sample design is used to produce a nationally representative sample of students in grades 9–12 attending public and private schools. In 2013, the first-stage sampling frame comprised primary sampling units (PSUs), consisting of counties, subareas of large counties, or groups of smaller, adjacent counties. PSUs were categorized into strata according to their metropolitan statistical area (MSA) status (i.e., urban city) and the percentages of black and Hispanic students in the PSUs. PSUs were sampled with probability proportional to overall school enrollment size for the PSU. In the second stage of sampling, schools with any of grades 9–12 were sampled with probability proportional to school enrollment size. The third stage of sampling consisted of random sampling in each of grades 9–12, one or two classrooms from either a required subject (e.g., English or social studies) or a required period (e.g., homeroom or second period).

All students in sampled classes were eligible to participate. Schools, classes, and students that refused to participate were not replaced. To enable a separate analysis of data for black and Hispanic students, two classes per grade, rather than one, were sampled in schools with a high enrollment of black and Hispanic students. Prior to 2013, three strategies were used to oversample black and Hispanic students: (a) larger sampling rates were used to select PSUs that were in high-black and high-Hispanic strata; (b) a modified measure of size was used to increase the probability of sampling schools with a disproportionately high minority enrollment; and (c) two classes per grade, rather than one, were sampled in schools with a high enrollment of black and Hispanic students. A weighting factor is applied to each student record to adjust for nonresponse and for the varying probabilities of selection, including those resulting from the oversampling of black and Hispanic students.

##### Sample Size and Response Rate

The sample size for the 2013 YRBS was 13,583 students in 148 schools. The school response rate was 77%, and the student response rate was 88%, for an overall response rate of 68%.

##### Issues Affecting Interpretation

National YRBS data are subject to at least two limitations. First, these data apply only to adolescents who attend regular high school, including some charter, public alternative, special education, and vocational schools. These students may not be representative of all persons in this age group because those who have dropped out of high school are not surveyed. Second, the extent of underreporting or overreporting cannot be determined, although the survey questions demonstrate good test-retest reliability.

Estimates of substance use for youth based on YRBS differ from the National Survey on Drug Use & Health (NSDUH) and the Monitoring the Future (MTF) Study. Rates are not directly comparable across these surveys because of differences in populations covered, sample design, questionnaires, and interview setting. NSDUH collects data in residences, whereas MTF and YRBS collect data in school classrooms. In addition, NSDUH estimates are tabulated by age, whereas MTF and YRBS estimates are tabulated by grade, representing different ages as well as different populations. All YRBS data collection is anonymous.

###### References

Brener ND, Kann L, Shanklin SL, Kinchen S, Eaton DK, Hawkins J, et al. Methodology of the Youth Risk Behavior Surveillance System—2013. MMWR. 2013;62(RR–1):1-23. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/rr6201a1.htm.
Kann L, Kinchen S, Shanklin SL, Flint KH, Hawkins J, Harris WA, et al. Youth Risk Behavior Surveillance—United States, 2013. MMWR Surveill Summ. 2014;63(SS–4):1-172. Available from: http://www.cdc.gov/mmwr/pdf/ss/ss6304.pdf.
Cowan CD. Coverage, sample design, and weighting in three federal surveys. J Drug Issues. 2001;31(3):599-614.

##### For More Information

See the YRBS website at: http://www.cdc.gov/yrbs.

## Private and Global Sources

### American Association of Colleges of Osteopathic Medicine (AACOM)

AACOM compiles data on various aspects of osteopathic medical education for distribution to the profession, the government, and the public. Questionnaires are sent annually to schools of osteopathic medicine requesting information on characteristics of applicants, students and graduates, faculty, curriculum, contract and grant activity, revenues and expenditures, and clinical facilities.

#### Reference

American Association of Colleges of Osteopathic Medicine. Trends in osteopathic medical school applicants, enrollment and graduates 2014. Chevy Chase, MD. AACOM. 2014.

#### For More Information

See the AACOM website at: http://www.aacom.org.

### American Association of Colleges of Pharmacy (AACP)

AACP compiles data on colleges and schools of pharmacy, including information on student enrollment and types of degrees conferred. Data are collected through an annual survey. In 2013, the response rate was 97.7%.

#### Reference

American Association of Colleges of Pharmacy. Fall 2013 profile of pharmacy students. Available from: http://www.aacp.org/resources/research/institutionalresearch/Pages/StudentApplications,EnrollmentsandDegreesConferred.aspx.

#### For More Information

See the AACP website at: http://www.aacp.org.

### American Association of Colleges of Podiatric Medicine (AACPM)

AACPM compiles data on colleges of podiatric medicine, including information on the schools and enrollment. Data are collected annually through written questionnaires. The response rate is 100%.

#### Reference

American Association of Colleges of Podiatric Medicine. Applicant, matriculant, and graduate statistics. Available from: http://www.aacpm.org.

#### For More Information

See the AACPM website at: http://www.aacpm.org.

### American Dental Association (ADA)

ADA’s Division of Educational Measurement conducts annual surveys of predoctoral dental educational institutions. A questionnaire, mailed to all dental schools, collects information on academic programs, admissions, enrollment, attrition, graduates, educational expenses and financial assistance, patient care, advanced dental education, and faculty positions.

#### Reference

American Dental Association. 2012–2013 Survey of dental education series. Report 1: Academic programs, enrollment and graduates. Chicago, IL. ADA. 2014. Available from: http://www.ada.org/en/science-research/health-policy-institute/data-center/dental-education.

#### For More Information

See the ADA website at: http://www.ada.org.

### American Hospital Association (AHA) Annual Survey of Hospitals

Data from AHA’s annual survey are based on questionnaires sent to all AHA-registered and nonregistered hospitals in the United States and its associated areas: American Samoa, Guam, the Marshall Islands, Puerto Rico, and the Virgin Islands. U.S. government hospitals located outside the United States are excluded. Overall, the average response rate over the past 5 years has been approximately 83%. For nonreporting hospitals and for the survey questionnaires of reporting hospitals on which some information was missing, estimates are made for all data except those on beds, bassinets, facilities, and services. Data for beds and bassinets of nonreporting hospitals are based on the most recent information available from those hospitals. Data for facilities and services are based only on reporting hospitals. Estimates of other types of missing data are based on data reported the previous year, if available. When unavailable, estimates are based on data furnished by reporting hospitals similar in size, control, major service provided, length of stay, and geographic and demographic characteristics.

#### Reference

American Hospital Association. Hospital statistics, 2014. Chicago, IL. AHA. 2014.

#### For More Information

See the AHA website at: http://www.aha.org.

### American Medical Association (AMA) Physician Masterfile

A master file of physicians has been maintained by AMA since 1906. The Physician Masterfile contains data on all physicians in the United States, both members and nonmembers of AMA, and on those graduates of American medical schools temporarily practicing overseas. The file also includes information on international medical graduates (IMGs) who are graduates of foreign medical schools, who reside in the United States, and who meet U.S. educational standards for primary recognition as physicians.

A file is initiated on each individual upon entry into medical school or, in the case of IMGs, upon entry into the United States. Between 1969 and 1985, a mail questionnaire survey was conducted every 4 years to update the file information on professional activities, self-designated area of specialization, and present employment status. Between 1985 and 2006, approximately one-third to one-fourth of all physicians were surveyed each year. Since then, AMA has employed a more diversified survey approach in which more than 500,000 active physicians are targeted each year through mail, telephone, and Web-based surveys.

#### Reference

American Medical Association, Division of Survey and Data Resources. Physician characteristics and distribution in the U.S., 2012. Chicago, IL. AMA. 2014.

#### For More Information

See the AMA website at: http://www.ama-assn.org.

### American Osteopathic Association (AOA)

AOA was established to promote the public health, to encourage scientific research, and to maintain and improve high standards of medical education in osteopathic colleges. Among its activities, AOA compiles the number of osteopathic physicians (DOs); the number of active DOs by gender, age, and specialty and by 50 states and D.C.; and the number of osteopathic medical students by selected characteristics.

#### Reference

American Osteopathic Association. Osteopathic medical profession report, 2010. Chicago, IL. AOA. 2012. Available from: http://www.osteopathic.org/inside-aoa/about/who-we-are/Documents/Osteopathic-Medical-Profession-Report-2010.pdf.

#### For More Information

See the AOA website at: http://www.osteopathic.org.

### Association of American Medical Colleges (AAMC)

As part of its mission to serve and lead the academic medicine community to improve the health of all, AAMC collects information on student enrollment in medical schools through a variety of sources. Among the data services and sources offered are the Medical College Admission Test (MCAT), the American Medical College Application Service (AMCAS), the Electronic Residency Application Service (ERAS), the online portfolio Pivio, and the Student Records System. The AAMC Data Warehouse (DW) stores data relevant to both applicants and students, and from these two source files the association derives summary statistics about applicants, accepted applicants, matriculants, enrollees, and graduates. AAMC has developed policies and procedures to ensure that the privacy of individual and institutional data are protected and meet federal, state, AAMC, and professional standards. Applicant, enrollment, and graduate statistical data are arranged by academic year, which begins July 1 and ends June 30.

#### Reference

Association of American Medical Colleges. AAMC data book: Medical schools and teaching hospitals by the numbers, 2014. Washington, DC. AAMC. 2014.

#### For More Information

See the AAMC website at: http://www.aamc.org.

### Association of Schools and Colleges of Optometry (ASCO)

ASCO compiles data on various aspects of optometric education, including data on schools and enrollment. Schools and colleges complete an annual questionnaire. The response rate is 100%.

#### Reference

Association of Schools and Colleges of Optometry. Annual student data report: Academic year 2013–2014. Rockville, MD. ASCO. 2014. Available from: http://www.opted.org/wp-content/uploads/2013/03/2-ASCO-2013-2014-Annual-Student-Data-Report.pdf.

#### For More Information

See the ASCO website at: http://www.opted.org.

### Association of Schools & Programs of Public Health (ASPPH)

ASPPH compiles data on schools of public health in the United States, Puerto Rico, Mexico, and Canada. Unlike health professional schools that emphasize specific clinical occupations, schools and programs of public health offer study in specialty areas such as biostatistics, epidemiology, environmental health, occupational health, health administration, health planning, nutrition, maternal and child health, social and behavioral sciences, and other population-based sciences. Data collection is conducted annually from all member schools, and data collection on programs will begin in 2014. The response rate is 100%.

#### Reference

Association of Schools and Programs of Public Health. Washington, DC. ASPPH. 2014.

#### For More Information

See the ASPH website at: http://www.aspph.org.

### Guttmacher Institute Abortion Provider Census

The Guttmacher Institute (previously called the Alan Guttmacher Institute, or AGI) is a not-for-profit organization for reproductive health research, policy analysis, and public education. Guttmacher has collected or estimated national abortion data since 1973 by conducting surveys every 3–4 years, and extrapolating estimates for the intervening years. Guttmacher reports the number of legal induced abortions and the number, types, and locations of abortion providers by state and region.

The abortion data reported to Guttmacher contain data on women of all ages, including adolescents who obtain legal induced abortions, and includes both surgical and medication (e.g., using mifepristone, misoprostol, or methotrexate) abortion procedures. Data are collected from three major categories of providers that were identified as potential providers of abortion services: clinics, physicians, and hospitals.

Questionnaires are mailed to all potential providers, with two additional mailings and telephone follow-up for nonresponse. All questionnaires ask the number of induced abortions performed at the provider’s location. State health statistics agencies are also contacted, requesting all available data reported by providers to each state health agency on the number of abortions performed in the survey year. For states that provide data to Guttmacher, the health agency figures are used for providers who do not respond to the survey. Estimates of the number of abortions performed by some providers are ascertained from knowledgeable sources, including other providers of reproductive health services.

In the 2012–2013 survey, respondents were asked to report the number of induced abortions performed in their facilities during 2010 and 2011. Of the 2,288 potential providers surveyed between April 2012 and May 2013, 1,222 responded directly or in follow-up; health department data were used for 470 providers; 71 facilities had closed or stopped offering abortion services during the survey period; knowledgeable sources were used for 51 providers; and Guttmacher made its own estimates for 474 facilities, usually relying on prior abortion census results. The level of internal estimation was higher than in the 2008 survey.

Between 2002 and 2011, the total number of abortions reported to CDC has been about one-third less than the total estimated by Guttmacher. (See Appendix I, Abortion Surveillance System.)

#### Reference

Jones RK, Jerman J. Abortion incidence and service availability in the United States, 2011. Perspect Sex Reprod Health. 2014;46(1):3-14. Available from: http://www.guttmacher.org/pubs/journals/psrh.46e0414.pdf. [pmid: 24494995].

#### For More Information

See The Guttmacher Institute website at: http://www.guttmacher.org.

### Organisation for Economic Co-operation and Development (OECD) Health Data

OECD provides annual data on statistical indicators for health and health systems collected from 34 member countries, with some time series going back to 1960.

OECD was established in 1961 with a mandate to promote policies to achieve the highest sustainable economic growth and a rising standard of living among member countries. The organization now comprises 34 member countries: Australia, Austria, Belgium, Canada, Chile, the Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hungary, Iceland, Ireland, Israel, Italy, Japan, Korea, Luxembourg, Mexico, the Netherlands, New Zealand, Norway, Poland, Portugal, the Slovak Republic, Slovenia, Spain, Sweden, Switzerland, Turkey, the United Kingdom, and the United States.

Each year, OECD compiles cross-country data in the OECD Health Data database, one of the most comprehensive sources of comparable health-related statistics.

#### For More Information

See the OECD website at: http://www.oecd.org/health.