# Utilization and Access

## Emergency Department Use

Children and adults aged 18–64 with Medicaid coverage were more likely to have at least one emergency department visit in the past year, compared with the uninsured and those with private coverage.

During 2002 through 2012, the percentage of children under age 18 with at least one emergency department visit in the past year declined for those with private coverage and for children with Medicaid coverage, while remaining stable for uninsured children. In 2012, 24.8% of children with Medicaid, 15.6% of uninsured children, and 13.0% of children with private coverage had an emergency department visit in the past year. During 2002 through 2012, the percentage of adults aged 18–64 with at least one emergency department visit was stable for those with Medicaid and for the uninsured. For adults with private coverage, the percentage with an emergency department visit declined during 2002 through 2012.

Figure 16 One or more emergency department visits in the past 12 months, by age and type of coverage: United States, 2002–2012

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig16

SOURCE: CDC/NCHS. Health, United States, 2013. Tables 86 and 87. Data from the National Health Interview Survey (NHIS). .

Figure 16 consists of two line graphs, one for children under age 18 and one for adults aged 18 to 64, showing one or more emergency department visits in the past 12 months, by type of coverage, for 2002 to 2012.

## Usual Source of Care Among Children

Uninsured children under age 18 were more likely than those with Medicaid and private coverage to lack a usual source of care.

Children benefit from having a usual source of health care for the provision of preventive services and treatment of acute and chronic conditions (24). During 2001–2002 through 2011–2012, the percentage of children without a usual source of care was stable for uninsured children and for those with private coverage, and decreased for those with Medicaid coverage. Throughout this period, uninsured children were more likely to lack a usual source of care than those with Medicaid or private coverage. In 2011–2012, 28.4% of uninsured children, 3.1% of children with Medicaid coverage, and 1.7% of those with private coverage lacked a usual source of care.

Figure 17 No usual source of care among children under age 18, by type of coverage: United States, average annual, 2001–2002 through 2011–2012

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig17

NOTE: Persons who reported the emergency department as their usual source of care were classified as not having a usual source of care.

SOURCE: CDC/NCHS. Health, United States, 2013. Table 72. Data from the National Health Interview Survey (NHIS). .

Figure 17 is a line graph showing no usual source of care among children under age 18, by health insurance status, for 2001 to 2002 (average annual) through 2011 to 2012 (average annual).

## Delay or Nonreceipt of Medical Care or Nonreceipt of Dental Care Due to Cost

During 2002 through 2012, the percentage of adults aged 18–64 who delayed or did not receive needed medical care in the past 12 months due to cost increased for those living below 400% of the poverty level; the percentage of adults who did not receive needed dental care due to cost increased for all family income groups.

During 2002–2012, the percentage of adults aged 18–64 who delayed or did not receive medical care in the past 12 months due to cost was higher for adults living below 200% of the poverty level than for those with higher family income (22.4% and 22.3%, compared with 13.2% for those at 200%–399% and 5.3% for those at 400% or more of the poverty level in 2012). Also during 2002 through 2012, nonreceipt of dental care due to cost was higher for adults living below 200% of the poverty level than for those with higher family income (26.9% and 25.3%, compared with 13.8% for those at 200%–399% and 5.5% for those at 400% or more of the poverty level in 2012).

Figure 18 Delay or nonreceipt of needed medical care or nonreceipt of needed dental care in the past 12 months due to cost among adults aged 18–64, by percent of poverty level: United States, 2002–2012

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig18

SOURCE: CDC/NCHS. Health, United States, 2013. Table 74. Data from the National Health Interview Survey (NHIS). .

Figure 18 consists of two line graphs for adults aged 18 to 64, one showing delay or nonreceipt of needed medical care due to cost and one showing nonreceipt of needed dental care due to cost, during the past 12 months, by percent of poverty level, for 2002 through 2012.