# Technical Notes

## Data Sources and Comparability

Data for the Health, United States, 2013 Chartbook come from many surveys and data systems and cover a broad range of years. Detailed descriptions of the data sources included in the Chartbook are provided in Appendix I. Additional information clarifying and qualifying the data are included in the table notes and in Appendix II. Definitions and Methods.

## Data Presentation

Many measures in the Chartbook are shown for people in specific age groups because of the strong effect of age on most health outcomes. Some estimates are age-adjusted using the age distribution of the 2000 standard population; where this has been done, it is noted in the data tables that accompany the charts. Age-adjusted rates are computed to eliminate differences in observed rates that result from age differences in population composition (see Appendix II, Age adjustment). For some charts, data years are combined to increase sample size and the reliability of the estimates. Some charts present time trends, and others focus on differences in estimates among population subgroups for the most recent time point available. Trends are generally shown on a linear scale to emphasize absolute differences over time. The time trends for the overall mortality measures are shown on a logarithmic (log) scale to emphasize the rate of change and to enable measures with large differences in magnitude to be shown on the same chart. Point estimates and standard errors for Figures 1–19 are available in the Trend Table and Excel spreadsheet specified in the Note below the chart. Data tables with point estimates and standard errors (when appropriate) accompany Figures 20–29. Some data tables contain additional data that were not graphed because of space considerations.

## Statistical Testing

Data trends can be described in many ways. For trend analyses presented in the Chartbook, increases or decreases in the estimates over time are measured by the annual percent change using the weighted least squares regression method. Statistically significant changes in the trend are assessed at the 0.05 level using the National Cancer Institute's Joinpoint software. For more information on Joinpoint, see: http://surveillance.cancer.gov/joinpoint/ For analyses that compare two time periods, differences between the two periods were assessed for statistical significance at the 0.05 level using two-sided significance tests (z-tests).

Terms such as “similar,” “stable,” and “no difference” used in the text indicate that the statistics being compared were not significantly different. Lack of comment regarding the difference between statistics does not necessarily suggest that the difference was tested and found to be not significant. Because statistically significant differences or trends are partly a function of sample size (the larger the sample, the smaller the change that can be detected), they do not necessarily have public health significance (81)).Testing and comparisons use the estimates and standard errors in the trend and data tables, not the rounded estimates shown in the charts.

Overall estimates generally have relatively small sampling errors, but estimates for certain population subgroups may be based on small numbers and have relatively large sampling errors. Numbers of deaths obtained from the National Vital Statistics System represent complete counts and therefore are not subject to sampling error. They are, however, subject to random variation, which means that the number of events that actually occur in a given year may be considered as one of a large series of possible results that could have arisen under the same circumstances. When the number of events is small and the probability of such an event is small, considerable caution must be observed in interpreting the conditions described by the charts. Estimates that are unreliable because of large sampling errors or small numbers of events have been noted with an asterisk. The criteria used to designate or suppress unreliable estimates are indicated in the notes to the applicable tables or charts.

For NCHS surveys, point estimates and their corresponding variances were calculated using the SUDAAN software package, which takes into consideration the complex survey design (82). Standard errors for other surveys or data sets were computed using the methodology recommended by the programs providing the data, or were provided directly by those programs.

## Survey Questions and Coding

Additional information on data used in the Special Feature, including exact wording of questions and coding schemes, is detailed below.

Figures 20–22 and 25. The National Health and Nutrition Examination Survey (NHANES) questionnaire administered to all participants included a question on whether they had taken a prescription drug in the past 30 days [RXDUSE]. Those who answered “yes” were asked to show the interviewer the medication containers for all the prescriptions. For each drug reported, the interviewer entered the product's complete name from the container. If no container was available, the interviewer asked the participant to verbally report the name of the drug. Only prescriptions the respondent themselves took are included. Prescriptions administered in other health care settings, such as physician offices and hospital outpatient departments, are not collected. Over-the-counter drugs play an important role in health care, but most of the analysis in this feature focuses only on prescription drugs.

More information on prescription drug data collection and coding in NHANES is available from: http://www.cdc.gov/nchs/nhanes/nhanes1999-2000/RXQ_DRUG.htm Also see Appendix I, National Health and Nutrition Examination Survey; Appendix II, Drug.

Figure 21. Data are from NHANES and are based on prescription drugs the respondent reported taking in the past 30 days. For each drug reported, the interviewer entered the product's complete name from the container and the drug was categorized into therapeutic classes. Drug classes cited are from Lexicon Plus (Cerner Multum, Denver, CO), a proprietary comprehensive database of all prescription and some nonprescription drug products available in the U.S. drug market.

- The category antiasthmatics includes one or more asthma drugs, including bronchodilators, mast cell stabilizers, inhaled corticosteroids, mucolytics, inhaled anti-infectives, leukotriene modifiers, and antiasthmatic combinations (level 2, class 125, 130, 131, or 243).
- The category antibiotics includes one or more antibiotic drugs, including antituberculosis agents, cephalosporins, leprostatics, macrolide derivatives, miscellaneous antibiotics, penicillins, quinolones, sulfonamides, tetracyclines, urinary anti-infectives, aminoglycosides, lincomycin derivatives, and glycopeptide antibiotics (level 2, class 6, 8-18, 240, 315, or 406).
- The category central nervous system stimulants includes one or more central nervous system stimulants (level 2, class 71).
- The category analgesics includes one or more analgesic drugs (level 2, class 58).
- The category antidepressants includes one or more antidepressant drugs (level 2, class 249).
- The category cardiovascular agents includes one or more cardiovascular agents, agents for hypertensive emergencies, ACE inhibitors, peripherally acting antiadrenergic agents, centrally acting antiadrenergic agents, antianginal agents, antiarrhythmic agents, beta-adrenergic blocking agents, calcium channel blocking agents, diuretics, inotropic agents, miscellaneous cardiovascular agents, peripheral vasodilators, vasodilators, vasopressors, antihypertensive combinations, angiotensin II inhibitors, agents for pulmonary hypertension, aldosterone receptor antagonists, renin inhibitors, anticholinergic chronotropic agents, and catecholamines (level 1, class 40).
- The category cholesterol-lowering drugs includes one or more antihyperlipidemic drugs (level 2, class 19).
- The category anti-acid reflux drugs includes one or more proton pump inhibitors or H_2_ antagonists (level 2, class 94 or 272).
- The category antidiabetic agents includes one or more antidiabetic drugs (level 2, class 99).
- The category anticoagulants includes one or more anticoagulants or antiplatelet agents (level 2, class 82 or 83).

Figure 23. Data are from National Health Interview Survey and are based on adults responding to the question, “During the past 12 months was there any time when you needed prescription medicine but didn't get it because [person] couldn't afford it?” [AHCAFYR1]. Survey respondents may be covered by health insurance at the time of interview but may have experienced one or more lapses in coverage during the 12 months prior to interview. To be consistent with the 12-month period used to determine prescription drug access issues, insurance status during the prior 12 months was used. Insurance status during the prior 12 months was determined using two questions: (a) all persons without a known comprehensive health insurance plan were asked, “About how long has it been since [person] last had health care coverage?” [HILAST]; and (b) all persons with known health insurance coverage were asked, “In the past 12 months, was there any time when [person] did NOT have ANY health insurance coverage?” [HINOTYR]. Also see Appendix II, Health insurance coverage.

Figure 26. Data are from the National Ambulatory Medical Care Survey and the National Hospital Ambulatory Medical Care Survey: Emergency Department and Outpatient Components. The following drugs codes were used to identify antibiotics: 00007, 00009, 00028, 00062, 00103, 00125, 00194, 00340, 00345, 00349, 00391, 01017, 01044, 01046, 01053, 01054, 01189, 01196, 01242, 01315, 01630, 01635, 01640, 01685, 01865, 02047, 02070, 02102, 02116, 02146, 02161, 02987, 03059, 03081, 03109, 03138, 03220, 03283, 03331, 03425, 03430, 03741, 04156, 04157, 04180, 04235, 04240, 04264, 04528, 04531, 04586, 05117, 05156, 05190, 05207, 05232, 05233, 05245, 05690, 05955, 05983, 05985, 05988, 05993, 05995, 06097, 06125, 06127, 06128, 06130, 06131, 06133, 06162, 06196, 06204, 06224, 06238, 06839, 06883, 06963, 07015, 07067, 07561, 07888, 08030, 08081, 08113, 08130, 08132, 08150, 08252, 08268, 08373, 08468, 08496, 08557, 08574, 08640, 09182, 09379, 09433, 09569, 09611, 09752, 09846, 09878, 09892, 10340, 10350, 10355, 10363, 10364, 10705, 10800, 10820, 10845, 10875, 10905, 11553, 11651, 11655, 11657, 11658, 11660, 11665, 11667, 11669, 11905, 12967, 13350, 13355, 15490, 15495, 16472, 16475, 16480, 16482, 16485, 17150, 17270, 18325, 18645, 19050, 19263, 19460, 19465, 19698, 20140, 20175, 20215, 20218, 20490, 21250, 21385, 21795, 22233, 22328, 22340, 22670, 22935, 23047, 23125, 23150, 23185, 23195, 23215, 23220, 23221, 23222, 23223, 23225, 23228, 23230, 23305, 23500, 23603, 23605, 24228, 24435, 24440, 24465, 24848, 25070, 25075, 25130, 25575, 26460, 26795, 26800, 26825, 26940, 26960, 27835, 27840, 28205, 28258, 28260, 28280, 28285, 28320, 29078, 29315, 29838, 29843, 29888, 29897, 30025, 30035, 30575, 30725, 30850, 31020, 31045, 31050, 31055, 31060, 31075, 31645, 31650, 31870, 32020, 32423, 32430, 33068, 33092, 33155, 33355, 33400, 33410, 33425, 33430, 33780, 33805, 34085, 34090, 34950, 34970, 34975, 34990, 35595, 40310, 41785, 50036, 60115, 60120, 60125, 60295, 60335, 60485, 60500, 60505, 60780, 61085, 61185, 61295, 61410, 61415, 61470, 89015, 89027, 89028, 89029, 89059, 89075, 89076, 91015, 91017, 91059, 91067, 91068, 91069, 91070, 91094, 92004, 92006, 92013, 92029, 92031, 92109, 92110, 92111, 92112, 92140, 93038, 93088, 93093, 93098, 93166, 93179, 93214, 93230, 93301, 93303, 93338, 93360, 93387, 93416, 93417, 94037, 94129, 94139, 94146, 94169, 95028, 95037, 95149, 95167, 95187, 96070, 96087, 97001, 97004, 97045, 97132, 97163, 98029, 98040, 98061, 98066, 98082, 99001, 99014, 99022, 99073, 99135.

Figure 27. Data are from the National Ambulatory Medical Care Survey (NAMCS), the National Hospital Ambulatory Medical Care Survey: Outpatient (NHAMCS–OPD) and Emergency Department (NHAMCS–ED) Components, and the National Survey of Residential Care Facilities (NSRCF).

Data from NAMCS, NHAMCS–OPD, and NHAMCS–ED were based on the following questions about the four types of computerized systems. The variable names are in this order: NAMCS, NHAMCS–OPD, NHAMCS–ED. If the provider reported that they had the system but it was turned off, they were classified as not having that computer system type. If the response was unknown, blank, or otherwise missing, the record was excluded from the analysis. Missing values can be handled in a variety of ways. Estimates in Health, United States may differ from other estimates based on the same data presented elsewhere if missing values were handled differently.

- Ordering prescriptions: “Does your practice have a computerized system for orders for prescriptions?” [ECPOE, ECPOEO, ECPOEE]. Six percent of physician offices, 6% of hospital OPDs, and 5% of hospital EDs had their ordering prescriptions systems turned off and were counted as not having an ordering prescriptions system.
- Warning of drug interactions and contraindications: “If practice has a computerized system for orders for prescriptions, are there warnings of drug interactions or contraindications provided?” Providers who did not have a system for ordering prescriptions or had it turned off (prior question) were not asked this question and were classified as not having a warning system [EWARN, EWARNO, EWARNE].
- Submitting prescriptions electronically to pharmacy: “If practice has a computerized system for orders for prescriptions, are prescriptions sent electronically to pharmacy?” Providers who did not have a system for ordering prescriptions or had it turned off (prior question) were not asked this question and were classified as not having a system to submit prescriptions electronically [ESCRIP, EESCRIPO, EESCRIPE].
- Including patient's allergies and current medications (in clinical notes system): Based on two questions, “If practice has a computerized system for clinical notes, do they include a comprehensive list of the patient's allergies (including allergies to medication)?” and “If practice has a computerized system for clinical notes, do they include a list of medications that the patient is taking?” Only providers with “Yes” to both questions were counted as having a system recording patient's allergies and medications. Providers who did not have a system for clinical notes or had it turned off (prior question) were not asked these questions and were classified as not having a system to record allergies and medications electronically [EMEDS, EMEDSO, EMEDSE, and EALLERG, EALLERGO, EALLERGE]. Five percent of physician offices, 4% of hospital OPDs, and less than 1% of hospital EDs had their clinical notes systems turned off and were counted as not having a patient's allergies or medications system.

Data from NSRCF were based on the following questions about the four types of computerized systems. Providers were shown a card with a list of computer systems and asked which types their facility had. If the response was unknown, blank, or otherwise missing, the record was excluded from the analysis.

- Ordering prescriptions: “Does this facility have the following computerized capabilities? ORDERS FOR PRESCRIPTIONS?” [ITPRESC].
- Warning of drug interactions and contraindications: “Does this facility have the following computerized capabilities? WARNING OF DRUG INTERACTIONS OR CONTRAINDICATIONS?” [ITCONTRA].
- Submitting prescriptions electronically to pharmacy: “Does this facility's computerized system support electronic health information exchange with PHARMACY?” [ITPHARM].
- Including patient's allergies and current medications (in clinical notes system): Based on two questions: “Does this facility have the following computerized capabilities? MAINTAINING ACTIVE MEDICATION ALLERGY LIST?” and “Does this facility have the following computerized capabilities? MAINTAINING LIST OF RESIDENT'S MEDICATIONS?” [ITRXLIST and ITALLERG].

Figure 28. Propoxyphene was withdrawn from the market in 2010. However, because the chart includes data back to 2000, propoxyphene is included in the list of synthetic drugs.

## References

1 Kochanek KD, Arias E, Anderson RN. How did cause of death contribute to racial differences in life expectancy in the United States in 2010?. NCHS data brief, no 125. Hyattsville, MD. NCHS. 2013. Available from: http://www.cdc.gov/nchs/data/databriefs/db125.htm.
2 Murphy SL, Xu J, Kochanek KD. Deaths: Final data for 2010. National vital statistics reports. Hyattsville, MD. NCHS. 2012;61(no 4). Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr61/nvsr61_04.pdf.
3 NCHS. 2010 mortality file. [unpublished analysis].
4 Altman B, Bernstein A. Disability and health in the United States, 2001-2005. Hyattsville, MD. NCHS. 2008. Available from: http://www.cdc.gov/nchs/data/misc/disability2001-2005.pdf.
5 U.S. Department of Health and Human Services. How tobacco smoke causes disease: The biology and behavioral basis for smoking-attributable disease: A report of the Surgeon General. Atlanta, GA. U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health. 2010. Available from: http://www.ncbi.nlm.nih.gov/books/NBK53017/pdf/TOC.pdf.
6 National High Blood Pressure Education Program. Seventh report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: Complete report. NIH pub no 04–5230. Bethesda, MD. National Heart, Lung, and Blood Institute, National Institutes of Health. 2004. Available from: http://www.nhlbi.nih.gov/guidelines/hypertension/jnc7full.htm.
7 Barlow SE, Expert Committee. Expert Committee recommendations regarding the prevention, assessment, and treatment of child and adolescent overweight and obesity: Summary report. Pediatrics. 2007;120(suppl 4):S164-92. Available from: http://pediatrics.aappublications.org/content/120/Supplement_4/S164.full.pdf+html. [pmid: 18055651].
8 Dietz WH. Health consequences of obesity in youth: Childhood predictors of adult disease. Pediatrics. 1998;101(3 pt 2):518-25. [pmid: 12224658].
9 National Heart, Lung, and Blood Institute, National Institute of Diabetes and Digestive and Kidney Diseases. Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults:The evidence report. NIH pub no 98–4083. Bethesda, MD. National Institutes of Health. 1998. Available from: http://www.nhlbi.nih.gov/guidelines/obesity/ob_gdlns.pdf.
10 Jensen MD, Ryan DH, Apovian CM, Ard JD, Comuzzie AG, Donato KA, et al. 2013 AHA/ACC/TOS guideline for the management of overweight and obesity in adults: A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines and the Obesity Society. Circulation. 2013. [doi: 10.1161/01.cir.0000437739.71477.ee]. Available from: http://circ.ahajournals.org/content/early/2013/11/11/01.cir.0000437739.71477.ee.citation.
11 National Task Force on the Prevention andTreatment of Obesity. Overweight, obesity, and health risk. Arch Intern Med. 2000;160(7):898-904. [pmid: 10761953].
12 U.S. Department of Health and Human Services. The Surgeon General's vision for a healthy and fit nation. Rockville, MD. HHS, Office of the Surgeon General. 2010. Available from: http://www.surgeongeneral.gov/initiatives/healthy-fit-nation/obesityvision2010.pdf.
13 Flegal KM, Graubard BI, Williamson DF, Gail MH. Excess deaths associated with underweight, overweight, and obesity. JAMA. 2005;293(15):1861-7. [pmid: 15840860].
14 CDC. Recommendations of the Advisory Committee on Immunization Practices (ACIP): General recommendations on immunization. MMWR. 2011;60(RR02):1-60. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/rr6002a1.htm?s_cid=rr6002a1_e.
15 CDC. Experiences with obtaining influenza vaccination among persons in priority groups during a vaccine shortage—United States, October–November, 2004. MMWR. 2004;53(49):1153-5. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm5349a2.htm.
16 CDC. Advisory Committee on Immunization Practices (ACIP) recommended immunization schedules for persons aged 0 through 18 years and adults aged 19 years and older—United States, 2013. MMWR. 2013;62(01):1-1. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/su6201a1.htm?s_cid=su6201a1_w.
17 CDC. National and state vaccination coverage among adolescents aged 13–17 years—United States, 2012. MMWR. 2013;62(34):685-93. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm6234a1.htm.
18 CDC. Quadrivalent human papillomavirus vaccine: Recommendations of the Advisory Committee on Immunization Practices (ACIP). MMWR. 2007;56(RR02):1-24. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/rr5602a1.htm?s_cid=rr5602a1_e.
19 CDC. Recommendations on the use of quadrivalent human papillomavirus vaccine in males–Advisory Committee on Immunization Practices (ACIP), 2011. MMWR. 2011;60(50):1705-8. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm6050a3.htm?s_cid=mm6050a3_w.
20 Kaiser Commission on Medicaid and the Uninsured. The uninsured and the difference health insurance makes. Kaiser Family Foundation. 2012. Available from: http://www.kff.org/uninsured/upload/1420-14.pdf.
21 Patient Protection and Affordable Care Act, Pub. L. No. 111–148, 124 Stat. 119, 132 (2010). Available from: http://www.gpo.gov/fdsys/pkg/PLAW-111publ148/content-detail.html.
22 Centers for Medicare & Medicaid Services, Center for Consumer Information and Insurance Oversight. Young adults and the Affordable Care Act: Protecting young adults and eliminating burdens on families and businesses. [fact sheet]. 2013. Available from: http://www.cms.gov/CCIIO/Resources/Files/adult_child_fact_sheet.html.
23 Sommers BD. Number of young adults gaining insurance due to the Affordable Care Act now tops 3 million. Washington, DC. US Department of Health and Human Services, Office of the Assistant Secretary for Planning and Evaluation. ASPE Issue Brief. 2012. Available from: http://www.aspe.hhs.gov/aspe/gaininginsurance/rb.pdf.
24 DeVoe JE, Petering R, Krois L. A usual source of care: Supplement or substitute for health insurance among low-income children?. Med Care. 2008;46(10):1041-8. [pmid: 18815525].
25 Peters CP. Fundamentals of the prescription drug market. NHPF Background Paper. Washington DC. National Health Policy Forum. 2004. Available from: http://www.nhpf.org/library/background-papers/BP_RxIndustry_08-24-04.pdf.
26 Greene JA, Jones DS, Podolsky SH. Therapeutic evolution and the challenge of rational medicine. N Engl J Med. 2012;367(12):1077-82. [pmid: 22992071].
27 Greene JA, Herzberg D. Hidden in plain sight: Marketing prescription drugs to consumers in the twentieth century. Am J Public Health. 2010;100(5):793-803. [pmid: 20299640].
28 CDC. Achievements in public health, 1900–1999: Control of infectious diseases. MMWR. 1999;48(29):621-9. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm4829a1.htm.
29 Gu Q, Dillon CF, Burt VL. Prescription drug use continues to increase: U.S. prescription drug data for 2007–2008. NCHS data brief, no 42. Hyattsville, MD. NCHS. 2010. Available from: http://www.cdc.gov/nchs/data/databriefs/db42.htm.
30 Howlader N, Noone AM, Krapcho M, Garshell J, Neyman N, Altekruse SF, et al., editors. SEER cancer statistics review (CSR), 1975–2010. Bethesda, MD. National Cancer Institute. 2013. Available from: http://seer.cancer.gov/csr/1975_2010/.
31 Go AS, Mozaffarian D, Roger VL, Benjamin EJ, Berry JD, Blaha MJ, et al. Heart disease and stroke statistics—2014 update: A report from the American Heart Association. Circulation. 2014;129(3):e28-e292. [pmid: 24352519].
32 Chobanian AV, Bakris GL, Black HR, Cushman WC, Green LA, Izzo JL Jr, et al. Seventh report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure. Hypertension. 2003;42(6):1206-52. [pmid: 14656957].
33 National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III). Third report of the NCEP Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III) final report. Circulation. 2002;106(25):3143-421. [pmid: 12485966].
34 American Diabetes Association. Diagnosis and classification of diabetes mellitus. Diabetes Care. 2013;36(suppl 1):S67-74. [pmid: 23264425].
35 Substance Abuse and Mental Health Services Administration. Mental health, United States, 2010. HHS Pub no (SMA) 12–4681. Rockville, MD. SAMHSA. 2012. Available from: http://www.samhsa.gov/data/2k12/MHUS2010/index.aspx.
36 Mechanic D, Bilder S. Treatment of people with mental illness: A decade-long perspective. Health Aff (Millwood). 2004;23(4):84-95. [pmid: 15318569].
37 Berndt ER. The U.S. pharmaceutical industry: Why major growth in times of cost containment?. Health Aff (Millwood). 2001;20(2):100-14. [pmid: 11260932].
38 Chockley N. The emerging impact of direct-to-consumer prescription drug advertising. Testimony before the Subcommittee on Consumer Affairs, Foreign Commerce and Tourism of the Senate Committee on Commerce, Science and Transportation. July. 24. 2001. Available from: http://www.nihcm.org/pdf/The_Emerging_Impact_of_Direct-toConsumer_Prescription_Drug_Advertising.pdf.
39 Kaiser Family Foundation. The Affordable Care Act three years post-enactment. Pub no 8429. Washington, DC. KFF. 2013. Available from: http://kaiserfamilyfoundation.files.wordpress.com/2013/04/84291.pdf.
40 U.S. Government Accountability Office. Prescription drugs: FDA oversight of direct-to-consumer advertising has limitations. Pub no GAO–03–177. Washington, DC. GAO. 2002. Available from: http://www.gao.gov/new.items/d03177.pdf.
41 Ventola CL. Direct-to-consumer pharmaceutical advertising: Therapeutic or toxic?. PT. 2011;36(10):669-84.
42 Donohue JM, Cevasco M, Rosenthal MB. A decade of direct-to consumer advertising of prescription drugs. N Engl J Med. 2007;357(7):673-81. [pmid: 17699817].
43 Gellad WF, Donohue JM, Zhao X, Zhang Y, Banthin JS. The financial burden from prescription drugs has declined recently for the nonelderly, although it is still high for many. Health Aff (Millwood). 2012;31(2):408-16. [pmid: 22323172].
44 Hartman M, Martin AB, Benson J, Catlin A. National Health Expenditure Accounts Team. National health spending in 2011: Overall growth remains low, but some payers and services show signs of acceleration. Health Aff (Millwood). 2013;32(1):87-99. [pmid: 23297275].
45 Ackerman S, Gonzales R. The context of antibiotic overuse. Ann Intern Med. 2012;157(3):211-2. [pmid: 22868840].
46 CDC. Antibiotic resistance threats in the United States, 2013. CDC Features. 2013. Available from : http://www.cdc.gov/features/antibioticresistancethreats/.
47 Jones CM, Mack KA, Paulozzi LJ. Pharmaceutical overdose deaths, United States, 2010. JAMA. 2013;309(7):657-9. [pmid: 23423407].
48 CDC. Vital signs: Overdoses of prescription opioid pain relievers—United States, 1999–2008. MMWR. 2011;60(43):1487-92. Available from: http://www.cdc.gov/mmwr/pdf/wk/mm60e1101.pdf.
49 Warner M, Chen LH, Makuc DM. Increase in fatal poisonings involving opioid analgesics in the United States, 1999–2006. NCHS data brief, no 22. Hyattsville, MD. NCHS. 2009. Available from: http://www.cdc.gov/nchs/data/databriefs/db22.htm.
50 Warner M, Chen LH, Makuc DM, et al. Drug poisoning deaths in the United States, 1980–2008. NCHS data brief, no 81. Hyattsville, MD. NCHS. 2011. Available from: http://www.cdc.gov/nchs/data/databriefs/db81.htm.
51 Qato DM, Alexander GC, Conti RM, Johnson M, Schumm P, Lindau ST. Use of prescription and over-the-counter medications and dietary supplements among older adults in the United States. JAMA. 2008;300(24):2867-78. [pmid: 19109115].
52 Bushardt RL, Massey EB, Simpson TW, Ariail JC, Simpson KN. Polypharmacy: Misleading, but manageable. Clin Interv Aging. 2008;3(2):383-9. [pmid: 18686760].
53 Berenbeim DM. Polypharmacy: Overdosing on good intentions. Manag Care Q. 2002;10(3):1-5. [pmid: 12476658].
54 National Committee for Quality Assurance. HEDIS 2013: Healthcare Effectiveness Data and Information Set. Vol. 1, Narrative. Washington, DC. NCQA. 2012. Available from: http://www.ncqa.org/HEDISQualityMeasurement/HEDISMeasures/HEDIS2013.aspx.
55 NCHS. National Health and Nutrition Examination Survey [unpublished analysis]. For more information, visit: http://www.cdc.gov/nchs/nhanes.htm.
56 Cunningham PJ, Felland LE. Falling behind: Americans' access to medical care deteriorates, 2003–2007. Track Rep. 2008;19:1-5. Available from: http://hschange.org/CONTENT/993/. [pmid: 18610514].
57 Mojtabai R, Olfson M. Medication costs, adherence, and health outcomes among Medicare beneficiaries. Health Aff (Millwood). 2003;22(4):220-9. [pmid: 12889771].
58 Piette JD, Heisler M, Wagner TH. Cost-related medication underuse among chronically ill adults: The treatments people forgo, how often, and who is at risk. Am J Public Health. 2004;94(10):1782-7. [pmid: 15451750].
59 CDC. Current trends mortality attributable to HIV infection/AIDS—United States, 1981–1990. MMWR. 1991;40(3):41-4. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/00001880.htm.
60 CDC. Mortality attributable to HIV infection/AIDS among persons aged 25–44 years—United States, 1990, 1991. MMWR. 1993;42(25):481-6. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/00021017.htm.
61 Fauci AS. Twenty-five years of HIV/AIDS [editorial]. Science. 2006;313(5786):409. [pmid: 16873613].
62 Sepkowitz KA. AIDS—The first 20 years. N Engl J Med. 2001;344(23):1764-72. [pmid: 11396444].
63 Weston R, Portsmouth S, Benzie A. An update on HAART: Part 1. Pharm J. 2006;276:631-4.
64 Weiss RA. Special anniversary review: Twenty-five years of human immunodeficiency virus research: Successes and challenges. Clin Exp Immunol. 2008;152(2):201-10. [pmid: 18373700].
65 Palella FJ Jr, Delaney KM, Moorman AC, Loveless MO, Fuhrer JF, Satten GA, et al. Declining morbidity and mortality among patients with advanced human immunodeficiency virus infection. N Engl J Med. 1998;338(13):853-60. [pmid: 9516219].
66 Venkatesh KK, Mayer KH, Carpenter CC. Low-cost generic drugs under the President's Emergency Plan for AIDS Relief drove down treatment cost; more are needed. Health Aff (Millwood). 2012;31(7):1429-38. [pmid: 22778332].
67 Vella S, Schwartländer B, Sow SP, Eholie SP, Murphy RL. The history of antiretroviral therapy and of its implementation in resource-limited areas of the world. AIDS. 2012;26(10):1231-41. [pmid: 22706009].
68 Pratt LA, Brody DJ. Depression in the United States household population, 2005–2006. NCHS data brief, no 7. Hyattsville, MD. NCHS. 2008. Available from: http://www.cdc.gov/nchs/data/databriefs/db07.pdf.
69 Substance Abuse and Mental Health Services Administration. Behavioral health, United States, 2012. HHS Pub no (SMA) 13–4797. Rockville, MD. SAMHSA. 2013. Available from: http://www.samhsa.gov/data/2012BehavioralHealthUS/2012-BHUS.pdf.
70 Pratt LA, Brody DJ, Gu Q. Antidepressant use in persons aged 12 and over: United States 2005–2008. NCHS data brief, no 67. Hyattsville, MD. NCHS. 2011. Available from: http://www.cdc.gov/nchs/data/databriefs/db76.pdf.
71 Olfson M, Marcus SC. National patterns in antidepressant medication treatment. Arch Gen Psychiatry. 2009;66(8):848-56. [pmid: 19652124].
72 Colgan R, Powers JH. Appropriate antimicrobial prescribing: Approaches that limit antibiotic resistance. Am Fam Physician. 2001;64(6):999-1004. [pmid: 11578036].
73 Blumenthal D, Tavenner M. The “meaningful use” regulation for electronic health records. N Engl J Med. 2010;363(6):501-4. [pmid: 20647183].
74 Kern LM, Barrón Y, Dhopeshwarkar RV, Edwards A, Kaushal R, HITEC Investigators. Electronic health records and ambulatory quality of care. J Gen Intern Med. 2013;28(4):496-503. [pmid: 23054927].
75 Hsiao CJ, Hing E, Socey TC, Cai B. Electronic health record systems and intent to apply for meaningful use incentives among office-based physician practices: United States, 2001–2011. NCHS data brief, no 79. Hyattsville, MD. NCHS. 2011. [BW1]. Available from: http://www.cdc.gov/nchs/data/databriefs/DB79.pdf.
76 Chou R, Fanciullo GJ, Fine PG, Adler JA, Ballantyne JC, Davies P, et al. Clinical guidelines for the use of chronic opioid therapy in chronic noncancer pain. J Pain. 2009;10(2):113-30. [pmid: 19187889].
77 Keehan SP, Cuckler GA, Sisko AM, Madison AJ, Smith SD, Lizonitz JM, et al. National health expenditure projections: Modest annual growth until coverage expands and economic growth accelerates. Health Aff (Millwood). 2012;31(7):1600-12. [pmid: 22692089].
78 Hoffman JM, Li E, Doloresco F, Matusiak L, Hunkler RJ, Shah ND, et al. Projecting future drug expenditures in U.S. nonfederal hospitals and clinics—2013. Am J Health Syst Pharm. 2013;70(6):525-39. [pmid: 23456407].
79 Martin AB, Hartman M, Whittle L, Catlin A. National Health Expenditure Accounts Team. National health spending in 2012: Rate of health spending growth remained low for the fourth consecutive year. Health Aff (Millwood). 2014;33(1):67-77. [pmid: 24395937].
80 Medicare Payment Advisory Commission (MedPAC). Report to the Congress: Medicare and the health care delivery system. Ch 6, Care needs for dual-eligible beneficiaries. Washington, DC. MedPAC. 2013. Available from: http://www.medpac.gov/chapters/Jun13_Ch06.pdf.
81 CDC. Youth Risk Behavior Survey (YRBS): Interpretation of YRBS trend data. 2012. Available from: http://www.cdc.gov/HealthyYouth/yrbs/pdf/YRBS_trend_interpretation.pdf.
82 SUDAAN. release 10.0.1 [computer software]. Research Triangle Park, NC. RTI International. 2009.