# Prevention

## Influenza and Pneumococcal Vaccination

During 2002 through 2012, influenza vaccination in the past 12 months increased among adults under age 65, while remaining stable among those aged 65 and over. The percentage of adults aged 65 and over who had ever received a pneumococcal vaccination increased during this period.

Vaccination of persons at risk for complications from influenza and invasive pneumococcal disease is an important public health strategy (14). During 2002 through 2012, influenza vaccination in the past 12 months for noninstitutionalized adults increased among those aged 18–49 and 50–64 but was stable among those aged 65 and over. Decreases in influenza vaccination coverage in 2005 were related to a vaccine shortage (15). During 2002 through 2012, the percentage of noninstitutionalized adults who had ever received pneumococcal vaccination was stable among high-risk persons aged 18–64, and increased among those aged 65–74 and 75 and over.

Figure 12 Influenza and pneumococcal vaccination among noninstitutionalized adults aged 18 and over, by type of vaccination and age: United States, 2002–2012

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig12

NOTE: See Table 82 for a definition of the high-risk category for pneumococcal vaccination.

SOURCE: CDC/NCHS. Health, United States, 2013. Tables 81 and 82. Data from the National Health Interview Survey (NHIS). .

Figure 12 consists of two line graphs, one showing influenza vaccination in the past 12 months and one showing pneumococcal vaccination ever, among adults aged 18 and over, by age group, for 2002 through 2012.

## Vaccination Coverage Among Adolescents Aged 13–17

Vaccination coverage for adolescents aged 13–17 varied by type of vaccine.

Early adolescence (ages 11–12) is the recommended time for adolescents to catch up on missed childhood vaccinations and to receive three vaccines specifically recommended for them—Tetanus and diphtheria toxoids (Tdap), Meningococcal conjugate (MenACWY), and Human papillomavirus (HPV) (16,17). In 2012, among adolescents aged 13–17 who had time to obtain the recommended vaccinations, 84.6% had received Tdap vaccine and 74.0% had received MenACWY vaccine (17). The HPV vaccination series was recommended for females starting in June 2006 and for males in October 2011 (18,19). In 2012, 33.4% of females aged 13–17 had received three or more doses of HPV vaccine. Among males, 6.8% of those aged 13–17 had completed the HPV series in 2012—the first year following the recommendation for males.

Figure 13 Vaccination coverage among adolescents aged 13–17, by type of vaccine: United States, 2012

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig13

^1^ The HPV vaccination series was recommended for males in October 2011.

SOURCE: CDC/NCHS. Health, United States, 2013. Table 80. Data from the National Center for Immunization and Respiratory Diseases, National Immunization Survey–Teen. .

Figure 13 consists of a bar chart showing vaccination coverage among adolescents aged 13 to 17 years, by type of vaccine for 2012.