# Personal Health Care Expenditures

## Major Source of Funds

Out-of-pocket spending for personal health care expenditures grew less rapidly than Medicare, federal and state Medicaid, and private insurance spending between 2001 and 2011.

Between 2001 and 2011, total personal health care expenditures grew from $1.3 trillion to $2.3 trillion (Table 115). During this period, the average annual growth in Medicare expenditures was 8.1%; for Medicaid (federal) it was 6.4%, for Medicaid (state) it was 5.5%, for private health insurance 5.8%, and for out-of pocket spending 3.9%. In 2011, private health insurance spending for personal health care expenditures was $786.1 billion; Medicare spending was $521.6 billion, out-of-pocket spending was $307.7 billion, Medicaid (federal) spending was $229.0 billion, and Medicaid (state) spending was $145.5 billion (Table 115).

Figure 19 Personal health care expenditures, by source of funds: United States, 2001–2011

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig19

NOTE: Average annual percent change computed from estimates shown in Table 115.

SOURCE: CDC/NCHS. Health, United States, 2013. Table 115. Data from the Centers for Medicare & Medicaid Services, National Health Expenditure Accounts (NHEA). .

Figure 19 is a line graph showing trends in personal health care expenditures, by source of funds, for 2001 through 2011.