# Natality

## Teenage Childbearing

Between 2002 and 2012, teenage birth rates declined among all racial and ethnic groups.

In 2012, 2.3% of births were to teenagers under age 18 and 5.5% were to women aged 18–19 (Table 4). Between 2002 and 2012, birth rates declined 39% for teenagers aged 15–17 and 29% for women aged 18–19 (Table 3). Birth rates were higher among Hispanic and non-Hispanic black teenagers than among other racial and ethnic groups. Since 2002, birth rates have decreased 48% for Hispanic teenagers aged 15–17 and 46% for non-Hispanic black teenagers in the same age group. Also during this period, birth rates for those aged 18–19 decreased 39% for Hispanic teenagers and 32% for non-Hispanic black teenagers.

Figure 5 Teenage childbearing, by maternal age and race and Hispanic origin: United States, 2002–2012

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig05

SOURCE: CDC/NCHS. Health, United States, 2013. Table 3. Data from the National Vital Statistics System (NVSS). .

Figure 5 consists of two line graphs, one for mothers aged 15 to 17 and one for mothers aged 18 to 19, showing childbearing rates, by race and Hispanic origin, for 2002 through 2012.