# Mortality

## Life Expectancy at Birth

The gap in life expectancy at birth between white persons and black persons persists but has narrowed since 1990.

Life expectancy is a measure often used to gauge the overall health of a population. Between 1980 and 2010, life expectancy at birth in the United States increased from 70.0 years to 76.2 years for males and from 77.4 years to 81.0 years for females. Racial disparities in life expectancy at birth persisted for both males and females in 2010 but have narrowed since 1990 (1). Life expectancy at birth was 8.2 years longer for white males than for black males in 1990, and 4.7 years longer for white males than for black males in 2010. In 1990, life expectancy at birth was 5.8 years longer for white females than for black females; by 2010, life expectancy at birth was 3.3 years longer for white females than for black females. In 2010, Hispanic males and females had longer life expectancy at birth than non-Hispanic white or non-Hispanic black males and females.

Figure 1 Life expectancy at birth, by selected characteristics: United States, 1980–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig01

NOTE: Life expectancy by Hispanic origin was available starting in 2006.

SOURCE: CDC/NCHS. Health, United States, 2013. Table 18. Data from the National Vital Statistics System (NVSS). .

Figure 1 consists of a line graph showing trends in life expectancy at birth, by race and sex, for 1980 through 2010, and a bar chart showing life expectancy at birth for 2010, by sex and race and Hispanic origin.

## Infant Mortality

Infant, neonatal, and postneonatal mortality rates declined between 2000 and 2010.

The infant mortality rate is the risk of death during the first year of life. The 2010 infant mortality rate of 6.15 per 1,000 live births—a historically low value—was 11% lower than in 2000. During the same period, the neonatal mortality rate (death rate among infants under 28 days, a subset of infant mortality) decreased 13% to 4.05 per 1,000 live births, and the postneonatal mortality rate (death rate among infants 28 days through 11 months, a subset of infant mortality) declined 8% to 2.10 per 1,000 live births.

Figure 2 Infant, neonatal, and postneonatal mortality rates: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig02

SOURCE: CDC/NCHS. Health, United States, 2013. Table 13 and reference 2. Data from the National Vital Statistics System (NVSS). .

Figure 2 is a line graph showing infant, neonatal, and postneonatal mortality rates for 2000 through 2010.

## Selected Causes of Death

Between 2000 and 2010, the all-cause age-adjusted death rate decreased 16% among males and 13% among females.

During this 10-year period, age-adjusted death rates among males declined 37% for stroke, 30% for heart disease, 16% for cancer, and 13% for chronic lower respiratory diseases, while the age-adjusted death rate for Alzheimer's disease increased 38%, and the age-adjusted death rate for unintentional injury was stable. Among females, age-adjusted death rates declined 35% for stroke, 32% for heart disease, and 12% for cancer, while the age-adjusted death rates increased 41% for Alzheimer's disease, and 16% for unintentional injuries. In 2010, age-adjusted death rates were higher for males than females for heart disease, cancer, chronic lower respiratory diseases, diabetes, and unintentional injuries; were similar for stroke; and were higher among females than males for Alzheimer's disease.

Figure 3 Age-adjusted death rates for selected causes of death for all ages, by sex: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig03

SOURCE: CDC/NCHS. Health, United States, 2013. Table 20. Data from the National Vital Statistics System (NVSS). .

Figure 3 consists of two line graphs, one for males and one for females, showing age-adjusted death rates for selected causes of death for all ages, for 2000 through 2010.

## Motor Vehicle-related Death Rates

Between 2000 and 2010, motor vehicle-related death rates declined among males and females aged 15–19 and 20–24.

Motor vehicle-related deaths are a significant cause of preventable death, accounting for 35,332 deaths in the United States in 2010 across all ages (3). Motor vehicle-related death rates were higher for males and females aged 15–24 than for most other age groups (Table 33). For males and females aged 15–19, motor vehicle-related death rates declined 47% from 2000 to 2010. Motor vehicle-related death rates declined 31% for males aged 20–24 and 26% for females in the same age group during this 10-year period.

Figure 4 Motor vehicle-related death rates among persons aged 15–24, by sex and age: United States, 2000 –2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig04

SOURCE: CDC/NCHS. Health, United States, 2013. Table 33. Data from the National Vital Statistics System (NVSS). .

Figure 4 is a line graph showing motor vehicle-related death rates among persons aged 15 to 24, by sex and age for 2000 through 2010.