# Morbidity

## Heart Disease Prevalence

During 2001–2002 through 2011–2012, heart disease prevalence remained stable among men and women in most age groups.

Heart disease is the leading cause of death in the United States for both males and females, accounting for 307,384 deaths among males and 290,305 deaths among females across all ages in 2010 (Table 22). During 2001–2002 through 2011–2012, heart disease prevalence remained stable among men and women in all age groups except among women aged 65 and over, where the prevalence declined. In 2011–2012, the prevalence of respondent-reported heart disease among adults aged 18–54 was similar for men and women; among adults aged 55 and over, the prevalence was higher for men than for women. In 2011–2012, 43.5% of men aged 75 and over reported having ever been told by a physician that they had heart disease, compared with 31.5% of women in the same age group.

Figure 6 Respondent-reported heart disease prevalence among adults aged 18 and over, by sex and age: United States, average annual, 2001–2002 through 2011–2012

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig06

SOURCE: CDC/NCHS. Health, United States, 2013. Table 44. Data from the National Health Interview Survey (NHIS). .

Figure 6 consists of two line graphs, one for men and one for women, showing respondent-reported heart disease prevalence among adults aged 18 and over, by sex and age group, for 2001 to 2002 (average annual) through 2011 and 2012 (average annual).