# Health Risk Factors

## Current Cigarette Smoking

During 2002 through 2012, cigarette smoking prevalence declined among high school seniors and among adults aged 18–44 and women aged 45–64.

Smoking is associated with an increased risk of heart disease, stroke, lung and other types of cancers, and chronic lung diseases (5). Between 2002 and 2012, cigarette smoking among students in grade 12 decreased from 27.4% to 19.3% for male students and from 25.5% to 14.5% for female students. During 2002 through 2012, the percentage of adults who smoked cigarettes declined for men and women aged 18–44 and for women aged 45–64, while remaining stable for men aged 45-64 and for men and women aged 65 and over. In 2012, 20.5% of adult men aged 18 and over and 15.8% of adult women were current cigarette smokers (Table 56).

Figure 8 Current cigarette smoking among high school seniors and adults aged 18 and over, by sex and age: United States, 2002–2012

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig08

SOURCE: CDC/NCHS. Health, United States, 2013. Tables 56 and 61. Data from the National Health Interview Survey (NHIS) and the Monitoring the Future (MTF) Study. .

Figure 8 consists of two line graphs, one for males and one for females, showing current cigarette smoking among high school seniors and adults aged 18 and over, by sex and age group, for 2002 through 2012.

## Uncontrolled High Blood Pressure

Although control of high blood pressure has improved since 1988–1994, nearly one-half of adults with hypertension had uncontrolled high blood pressure in 2009–2012.

Hypertension increases the risk for cardiovascular disease, including heart attack and stroke (6). Between 1988–1994 and 2009–2012, the prevalence of uncontrolled high blood pressure (defined as an average systolic blood pressure of 140 mm Hg or higher, or an average diastolic pressure of 90 mm Hg or higher, among those with hypertension) declined for all age groups of men and women. However, nearly one-half (47.4%) of adults aged 20 and over with hypertension continued to have uncontrolled high blood pressure in 2009–2012 (Table 65).

Figure 9 Uncontrolled high blood pressure among adults aged 20 and over with hypertension, by sex and age: United States, 1988–1994 through 2009–2012

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig09

SOURCE: CDC/NCHS. Health, United States, 2013. Table 65. Data from the National Health and Nutrition Examination Survey (NHANES). .

Figure 9 consists of two line graphs, one for men and one for women, showing uncontrolled high blood pressure among adults aged 20 and over for adults with hypertension, by age group, for four time periods: 1988 to 1994, 1999 to 2002, 2003 to 2006, and 2009 to 2012.

## Obesity Among Children

Between 2003–2004 and 2011–2012, the prevalence of obesity among children aged 2–5 decreased, while the prevalence of obesity among older children and adolescents remained stable.

Excess body weight in children is associated with excess morbidity in childhood and adulthood (7,8). Obesity among children is defined as a body mass index at or above the sex- and age-specific 95th percentile of the CDC growth charts. The percentage of children aged 2–5 who were obese decreased from 14.0% in 2003–2004 to 8.4% in 2011–2012. The prevalence of obesity among children aged 6–11 and adolescents aged 12–19 was stable between 2003–2004 and 2011–2012. In 2011–2012, 17.7% of children aged 6–11 and 20.5% of adolescents aged 12–19 were obese.

Figure 10 Obesity among children and adolescents, by age: United States, 2003–2004 through 2011–2012

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig10

SOURCE: CDC/NCHS. Health, United States, 2013. Table 64. Data from the National Health and Nutrition Examination Survey (NHANES). .

Figure 10 is a line graph showing trends in obesity among children and adolescents, by age group, for 2003 to 2004 through 2011 to 2012.

## Overweight and Obesity Among Adults

In 2009–2012, the percentage of adults aged 20 and over with Grade 1 obesity was higher for men than women, and the percentage with Grade 2 or Grade 3 obesity was higher for women than men.

Reducing the prevalence of obesity is a public health priority because obesity is correlated with excess morbidity and mortality (9–12). In particular, Grade 2 or higher obesity [a body mass index (BMI) of 35 or higher] significantly increases the risk of death (13). Between 1988–1994 and 2009–2012, the percentage of men and women aged 20 and over who were overweight but not obese (BMI greater than or equal to 25 but less than 30) was stable. During this period, the percentage of adults aged 20 and over with Grade 1 obesity (BMI greater than or equal to 30 but less than 35), Grade 2 obesity (BMI greater than or equal to 35 but less than 40), and Grade 3 obesity (BMI of 40 or higher) increased among both men and women. In 2009–2012, 4.4% of men and 8.2% of women aged 20 and over had Grade 3 obesity.

Figure 11 Overweight and obesity among adults aged 20 and over, by sex: United States, 1988–1994 through 2009–2012

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig11

SOURCE: CDC/NCHS. Health, United States, 2013. Table 69. Data from the National Health and Nutrition Examination Survey (NHANES). .

Figure 11 consists of two area graphs, one for men and one for women, showing overweight but not obese, and grade 1, grade 2, and grade 3 obesity, among adults aged 20 and over, for four time periods: 1988 to 1994, 1999 to 2002, 2003 to 2006 and 2009-2012.