# Health Insurance

## Coverage Among Adults Aged 18–64

During 2002 through 2012, the percentage of adults aged 18–44 and 45–64 with private health insurance coverage decreased, while the percentage with Medicaid and the percentage uninsured increased.

Health insurance is a major determinant of access to health care (20). Among adults aged 18–44, the percentage with private coverage declined from 68.7% in 2002 to 61.4% in 2012, while the percentage with Medicaid coverage increased from 7.1% to 11.6%. The percentage of adults aged 18–44 who were uninsured increased from 23.0% to 24.8% during this period (also see Figure 15). Similarly, the percentage of adults aged 45–64 with private coverage declined from 77.3% in 2002 to 70.0% in 2012. The percentage of adults aged 45–64 with Medicaid coverage increased from 5.3% to 8.0%, and the percentage uninsured increased from 13.1% to 15.6%.

Figure 14 Health insurance coverage among adults aged 18–64, by age and type of coverage: United States, 2002–2012

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig14

NOTES: The Medicaid category includes the Children's Health Insurance Program (CHIP). Adults categorized as having Medicaid or private coverage may have additional types of health insurance coverage.

SOURCE: CDC/NCHS. Health, United States, 2013. Tables 122, 124, and 125. Data from the National Health Interview Survey (NHIS). .

Figure 14 consists of two line graphs, one for adults aged 18 to 44 and one for adults aged 45 to 64, showing health insurance coverage by type of coverage, for 2002 through 2012.

## Coverage Among Adults Aged 19–25

Between 2010 and 2012, the percentage of adults aged 19–25 who were uninsured decreased from 33.8% to 26.3%.

Historically, adults aged 19–25 have experienced high levels of uninsurance (Table 125). The percentage of adults aged 19–25 with private coverage declined from 59.3% in 2002 to 51.8% in 2010 and then rose to 58.1% in 2012. Between 2002 and 2010, the percentage of adults aged 19–25 who were uninsured fluctuated between 30.5% and 33.8%, and then decreased from 33.8% in 2010 to 26.3% in 2012. The section of the Patient Protection and Affordable Care Act (ACA) that allows most young adults to remain on their parent's coverage until age 26 came into effect with the policy year that began after September 23, 2010 (21–23). The percentage of adults aged 19–25 with Medicaid coverage [a category that includes the Children's Health Insurance Program (CHIP)] increased from 9.0% in 2002 to 12.6% in 2010 and was 13.4% in 2012.

Figure 15 Health insurance coverage among adults aged 19–25, by type of coverage: United States, 2002–2012

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig15

NOTE: Adults categorized as having Medicaid or private coverage may have additional types of health insurance coverage.

SOURCE: CDC/NCHS. Health, United States, 2013. Tables 122, 124, and 125. Data from the National Health Interview Survey (NHIS). .

Figure 15 is a line graph showing trends in health insurance coverage among adults aged 19 to 25, by type of coverage, for 2002 through 2012.