# Acknowledgments

Overall responsibility for planning and coordinating the content of this volume rested with the National Center for Health Statistics' (NCHS) Office of Analysis and Epidemiology, under the direction of Julia S. Holmes and Irma E. Arispe.

Production of Health, United States, 2013, including highlights, trend tables, and appendixes, was managed by Sheila J. Franco, Virginia M. Freid, and Julia S. Holmes. Trend tables were prepared by Mary Ann Bush, La-Tonya D. Curl, Anne K. Driscoll, Catherine R. Duran, Sheila J. Franco, Virginia M. Freid, Nancy Han, Hashini S. Khajuria, Ji-Eun Kim, Xianfen Li, Naga Shanmugam, and Rashmi Tandon, with assistance from Anita L. Powell and Ilene B. Rosen. The index was assembled by Anita L. Powell. Review and clearance books were assembled by Ilene B. Rosen. Administrative and word processing assistance was provided by Lillie C. Featherstone.

Production of the Chartbook was managed by Sheila J. Franco and Virginia M. Freid. The Special Feature on Prescription Drugs was prepared and written by Sheila J. Franco. Data and analysis for specific charts were provided by Sheila J. Franco, Virginia M. Freid, Hashini S. Khajuria, and Ji-Eun Kim. Charts were drafted by La-Tonya D. Curl. Technical assistance and programming were provided by Mary Ann Bush, La-Tonya D. Curl, Catherine R. Duran, Xianfen Li, Nancy Han, and Rashmi Tandon.

Publication production was performed by CDC/OSELS/ NCHS/OD/Office of Information Services, Information Design and Publishing Staff (IDPS). Project management and editorial review were provided by Barbara J. Wassell. Graphic design was provided by Dorothy M. Day, Odell D. Eldridge (contractor), and Kyung M. Park. Layout and production were done by Jacqueline M. Davis and Zung T. Le. Overview for IDPS publications and electronic products was provided by Christine J. Brown, Kimberly N. Ross, and Tommy C. Seibert, Jr. Printing was managed by Nathanael Brown, CDC/OD/OADC.

Electronic access through the NCHS website was provided by Christine J. Brown, La-Tonya D. Curl, Jacqueline M. Davis, Virginia M. Freid, Elom L. Lawson , Zung T. Le, Anthony Lipphardt, Kyung M. Park, Anita L. Powell, Anthony R. Quintana, Sharon L. Ramirez, Ilene B. Rosen, Naga Shanmugam, and Barbara J. Wassell.

Data and technical assistance were provided by staff of the following NCHS organizations: Division of Health Care Statistics: Michael Albert, Carol J. DeFrances, Chun-Ju Hsiao, Eric Jamoom, Linda F. McCaig, Susan M. Schappert, and Sayeedha Uddin; Division of Health and Nutrition Examination Surveys: Namanjeet Ahluwalia, Margaret D. Carroll, Mark S. Eberhardt, Qiuping Gu, Brian K. Kit, Cynthia L. Ogden, Ryne Paulose-Ram, and Sung Sug (Sarah) Yoon; Division of Health Interview Statistics: Patricia F. Adams, Veronica E. Benson, Debra Blackwell, Barbara Bloom, Tainya Clarke, Robin A. Cohen, Gulnur Freeman, Lindsey Jones, Whitney Kirzinger, Jacqueline Lucas, Michael Martinez, Jeannine Schiller, Charlotte A. Schoenborn, and Brian W. Ward; Division of Vital Statistics: Robert N. Anderson, Elizabeth Arias, Sally C. Curtin, Brady Hamilton, Sharon E. Kirmeyer, Kenneth D. Kochanek, Marian MacDorman, Joyce A. Martin, T.J. Mathews, Sherry L. Murphy, Michelle Osterman, Marie Thoma, Stephanie J. Ventura, Margaret Warner, and Elizabeth Wilson; Office of Analysis and Epidemiology: Lara Akinbami, Li-Hui Chen, Catherine R. Duran, Holly Hedegaard, Deborah D. Ingram, Laura A. Pratt, Cheryl V. Rose, Alan Simon, Ritu Tuteja, and Sirin Yaemsiri; Office of Policy, Budget, and Legislation: Andrea MacKay; Office of the Center Director: Juan Albertorio and Francis C. Notzon; and Office of Research and Methodology: Meena Khare.

Additional data and technical assistance were provided by the following organizations of the Centers for Disease Control and Prevention (CDC): National Center for Chronic Disease Prevention and Health Promotion: Karen Pazol; National Center for HIV/AIDS, Viral Hepatitis, STD, and TB Prevention: Anna Satcher Johnson and Rachel Stern Wynn; Office of Public Health Scientific Services, Center for Surveillance, Epidemiology, and Laboratory Services: Ruth Ann Jajosky; National Institute for Occupational Safety and Health: Roger Rosa; by the following organizations within the Department of Health and Human Services: Agency for Healthcare Research and Quality: Roxanne Andrews, Kellyn Carper, David Kashihara, and Steven R. Machlin; Centers for Medicare & Medicaid Services: Mary Carol Barron, Joseph Benson, Aaron Catlin, Cathy Cowan, Maria Diacogiannis, Bridget Dickensheets, Nathan Espinosa, Micah Hartman, Deborah W. Kidd, Barbara S. Klees, David Lassman, Anne Martin, Maggie S. Murgolo, Arun Natarajun, Jason G. Petroski, Joseph F. Regan, Benjamin E. Washington and Lekha Whittle; National Institutes of Health: Brenda Edwards, Missy Jamison, and Marsha Lopez; Substance Abuse and Mental Health Services Administration: Joe Gfroerer and Beth Han; and by the following governmental and nongovernmental organizations: U.S. Census Bureau: Bernadette D. Proctor; Bureau of Labor Statistics: Christen Byler and Audrey Watson; Department of Veterans Affairs: Tom Garin, Pheakdey Lim, and Dat Tran; American Association of Colleges of Pharmacy: Jennifer M. Patton; American Association of Colleges of Osteopathic Medicine: Lindsey Jurd; American Association of Colleges of Podiatric Medicine: Kelly Foster and Moraith G. North; American Dental Education Association: Sylvia M. Zeno; Association of American Medical Colleges: Geoffrey Redden; Association of Schools and Colleges of Optometry: Joanne Zuckerman; Association of Schools of Public Health: Kristin C. Dolinski; Cowles Research Group: C. McKeen Cowles; and NOVA Research Company: Shilpa Bengeri.