# Disability Measures

## Basic Actions Difficulty and Complex Activity Limitation

During 2002 through 2012, the percentage of the noninstitutionalized population with basic actions difficulty and the percentage of the noninstitutionalized population with complex activity limitation increased with age.

Basic actions difficulty and complex activity limitation are two constructs for defining and measuring disability status (4). Basic actions difficulty captures limitations in movement, emotional, sensory, or cognitive functioning associated with a health problem. Complex activity limitation is the inability to function successfully in certain social roles, such as working, maintaining a household, living independently, or participating in community activities. In 2012, the prevalence of each disability measure was higher for women than men in the same age group, with the exception of complex activity limitation among those aged 18–64, where the prevalence was similar for men and women (12.0%–12.9%).

Figure 7 Basic actions difficulty and complex activity limitation among adults aged 18 and over, by sex and age: United States, 2002–2012

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2013.htm#fig07

SOURCE: CDC/NCHS. Health, United States. 2013. Table 49. Data from the National Health Interview Survey (NHIS). .

Figure 7 consists of two line graphs, one showing basic actions difficulty and one showing complex activity limitation, among adults aged 18 and over, by sex and age group, for 2002 through 2012.