# Chartbook With Special Feature on Prescription Drugs

Mortality

Natality

Morbidity

Disability Measures

Health Risk Factors

Prevention

Health Insurance

Utilization and Access

Personal Health Care Expenditures

Special Feature on Prescription Drugs

Technical Notes