# Appendixes

Appendix I Data Sources

Appendix II Definitions and Methods