# Utilization and Access

## Prescription Drug Use

Between 1988–1994 and 2007–2010, the percentage of children and adults who had used three or more prescription drugs in the past 30 days increased.

In the United States, spending for prescription drugs was $259 billion in 2010, accounting for 12% of personal health care expenditures (Table 113). Between 1988–1994 and 2007–2010, the use of three or more prescription drugs in the past 30 days increased for all age groups of males and females. Some of the most commonly used prescription medications were asthma medicines and central nervous system stimulants for children and adolescents, antidepressants for middle-aged adults, and cholesterol-lowering and high blood pressure control drugs for older Americans (Table 92).

Figure 16 Use of three or more prescription drugs in the past 30 days, by sex and age: United States, 1988–1994, 1999–2002, and 2007–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2012.htm#fig16

SOURCE: CDC/NCHS, Health, United States, 2012, Table 91. Data from the National Health and Nutrition Examination Survey (NHANES).

Figure 16 consists of two line graphs, one for males and one for females, showing use of three or more prescription drugs in the past 30 days, by age group, for three time periods: 1988 to 1994, 1999 to 2002, and 2007 to 2010.

## Primary Care Generalist and Specialty Care Physician Office Visits

In 2010, 19% of office visits made by children under age 18 were to specialty care physicians, as were 37% of visits by adults aged 18–44, more than one-half of visits by those aged 45–64, and nearly two-thirds of visits by those aged 65 and over.

In 2010, there were 1 billion physician office visits in the United States (Table 88). The pattern of visits to primary care physicians (those in the fields of general and family practice, general internal medicine, general obstetrics and gynecology, and general pediatrics), compared with visits to specialty care physicians, differed by age. In 2010, physician office visits for children were more likely to be to primary care physicians than to specialty care physicians. For adults, the share of visits to specialty care physicians increased with rising age. Among adults aged 65 and over, nearly two-thirds of physician office visits were to specialty care physicians.

Figure 17 Visits to primary care generalist and specialty care physicians, by age: United States, 2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2012.htm#fig17

SOURCE: CDC/NCHS, Health, United States, 2012, Table 89. Data from the National Ambulatory Medical Care Survey (NAMCS).

Figure 17 consists of four pie charts showing visits to primary care generalist and specialty care physicians, by age group, for 2010.

## Delay or Nonreceipt of Needed Medical Care or Prescription Drugs Due to Cost

During 2001 through 2011, the percentage of adults aged 18–64 who delayed or did not receive needed medical care or prescription drugs due to cost increased for the uninsured and those with private coverage.

During 2001 through 2011, delay or nonreceipt of needed medical care in the past 12 months due to cost for those aged 18–64 increased among those with private coverage and the uninsured while remaining stable among those with Medicaid. In each year during this period, the percentage of adults aged 18–64 who delayed or did not receive medical care in the past 12 months due to cost was highest for the uninsured. Also during this period, the percentage of adults aged 18–64 who did not receive needed prescription drugs in the past 12 months due to cost increased among those with private coverage and the uninsured and was stable among those with Medicaid. Nonreceipt of prescription drugs was highest for the uninsured across all years.

Figure 18 Delay or nonreceipt of needed medical care or prescription drugs in the past 12 months due to cost among adults aged 18– 64, by type of coverage: United States, 2001–2011

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2012.htm#fig18

SOURCE: CDC/NCHS, Health, United States, 2012, Table 73. Data from the National Health Interview Survey (NHIS).

Figure 18 consists of two line graphs for adults aged 18 to 64, with one showing those who did not get or delayed needed medical care in the past 12 months due to cost and one showing those who did not get needed prescription drugs in the past 12 months due to cost, by type of health insurance coverage, for 2001 through 2011.