# References for Figures 1–19

1 Murphy SL, Xu JQ, Kochanek KD. Deaths: Final data for 2010. National vital statistics reports. Hyattsville, MD. NCHS. 2012;61(4). Available from: http://www.cdc.gov/nchs/data/nvsr/nvsr61/nvsr61_04.pdf.
2 Altman B, Bernstein A. Disability and health in the United States, 2001–2005. Hyattsville, MD. NCHS. 2008. Available from: http://www.cdc.gov/nchs/data/misc/disability2001-2005.pdf.
3 How tobacco smoke causes disease: The biology and behavioral basis for smoking-attributable disease. A report of the Surgeon General. Rockville, MD. U.S. Department of Health and Human Services, Public Health Service, Office of the Surgeon General. 2010. Available from: http://www.surgeongeneral.gov/library/reports/tobaccosmoke/full_report.pdf.
4 National High Blood Pressure Education Program. Seventh report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: Complete report. NIH pub no 04-5230. Bethesda, MD. National Heart, Lung, and Blood Institute, National Institutes of Health. 2004. Available from: http://www.nhlbi.nih.gov/guidelines/hypertension/jnc7full.htm.
5 Dietz WH. Health consequences of obesity in youth: Childhood predictors of adult disease. Pediatrics. 1998;101(3 pt 2):518-25. [pmid: 12224658].
6 Ogden CL, Carroll MD, Curtin LR, Lamb MM, Flegal KM. Prevalence of high body mass index in U.S. children and adolescents, 2007–2008. JAMA. 2010;303(3):242-9. [pmid: 20071470].
7 National Heart, Lung, and Blood Institute and National Institute of Diabetes and Digestive and Kidney Diseases. Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults: The evidence report. NIH pub no 98-4083. Bethesda, MD. National Institutes of Health. 1998. Available from: http://www.nhlbi.nih.gov/guidelines/obesity/ob_gdlns.pdf.
8 National Task Force on the Prevention and Treatment of Obesity. Overweight, obesity, and health risk. Arch Intern Med. 2000;160(7):898-904. [pmid: 10761953].
9 Flegal KM, Graubard BI, Williamson DF, Gail MH. Excess deaths associated with underweight, overweight, and obesity. JAMA. 2005;293(15):1861-7. [pmid: 15840860].
10 CDC. Recommendations of the Advisory Committee on Immunization Practices (ACIP): General recommendations on immunization. MMWR. 2011;60(RR–02):1-60. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/rr6002a1.htm?s_cid=rr6002a1_e.
11 CDC. Experiences with obtaining influenza vaccination among persons in priority groups during a vaccine shortage—United States, October–November, 2004. MMWR. 2004;53(49):1153-5. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm5349a2.htm.
12 U.S. Preventive Services Task Force. Screening for colorectal cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2008;149(9):627-37. Available from: http://www.uspreventiveservicestaskforce.org/uspstf08/colocancer/colors.pdf. [pmid: 18838716].
13 CDC. Vital Signs: Colorectal cancer screening among adults aged 50–75 years—United States, 2008. MMWR. 2010;59(26):808-12. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm5926a3.htm?s_cid=mm5926a3_w.
14 Kaiser Commission on Medicaid and the Uninsured. The uninsured and the difference health insurance makes. Kaiser Family Foundation. 2012. Available from: http://www.kff.org/uninsured/upload/1420-14.pdf.
15 Patient Protection and Affordable Care Act, Pub. L. No. 111-148, 124 Stat. 119, 132. 2010. Available from: http://www.gpo.gov/fdsys/pkg/PLAW-111publ148/content-detail.html.
16 Young adult coverage. U.S. Department of Health and Human Services. 2012. Available from: http://www.healthcare.gov/law/features/choices/young-adult-coverage/index.html.
17 Sommers BD. Number of young adults gaining insurance due to the Affordable Care Act now tops 3 million Washington, DC: US Department of Health and Human Services, Office of the Assistant Secretary for Planning and Evaluation. ASPE Issue Brief. 2012. Available from: http://www.aspe.hhs.gov/aspe/gaininginsurance/rb.pdf.