# Prevention

## Influenza and Pneumococcal Vaccination

Between 2001 and 2011, influenza vaccination in the past 12 months increased among adults under age 65, while remaining stable among those aged 65 and over. The percentage of adults aged 65 and over who had ever received a pneumococcal vaccination increased during this period.

Vaccination of persons at risk for complications from influenza and invasive pneumococcal disease is an important public health strategy (10). Between 2001 and 2011, influenza vaccination in the past 12 months for noninstitutionalized adults increased among those aged 18–49 and 50–64 but was stable among those aged 65 and over. Decreases in influenza vaccination coverage in 2005 were related to a vaccine shortage (11). Between 2001 and 2011, the percentage of noninstitutionalized adults who had ever received pneumococcal vaccination increased among those aged 65–74 and 75 and over.

Figure 12 Influenza and pneumococcal vaccination among adults aged 18 and over, by type of vaccination and age: United States, 2001–2011

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2012.htm#fig12

SOURCE: CDC/NCHS, Health, United States, 2012, Tables 80 and 81. Data from the National Health Interview Survey (NHIS).

Figure 12 consists of two line graphs, one showing influenza vaccination in the past 12 months and one showing pneumococcal vaccination ever, by age group, for 2001 through 2011.

## Colorectal Tests or Procedures

Between 2000 and 2010, the use of colorectal tests or procedures among adults aged 50–75 increased for all racial and ethnic groups.

Colorectal cancer is the third most common cancer in the United States. Death rates for colorectal cancer are highest among black persons (12,13) (Table 20). In 2008, the U.S. Preventive Services Task Force recommended colorectal cancer screening for adults aged 50–75 (12). Between 2000 and 2010, the percentage of adults aged 50–75 with a colorectal test or procedure increased for all racial and ethnic groups, primarily due to increased use of colonoscopy. Throughout this period, use of colorectal tests or procedures among those aged 50–75 was higher among non-Hispanic white persons and non-Hispanic black persons and lower among Hispanic persons and Asian persons.

Figure 13 Colorectal tests or procedures among adults aged 50–75, by race and Hispanic origin: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2012.htm#fig13

NOTE: The colonoscopy estimate for Asian adults in 2000 has a relative standard error of 20%–30%.

SOURCE: CDC/NCHS, Health, United States, 2012, Table 84. Data from the National Health Interview Survey (NHIS).

Figure 13 consists of two line graphs showing colorectal tests or procedures among adults aged 50 to 75, by race and Hispanic origin, for 2000 through 2010.