# Personal Health Care Expenditures

## Major Source of Funds

Out-of-pocket spending for personal health care expenditures grew less rapidly than Medicare, federal and state Medicaid, and private insurance spending between 2000 and 2010.

Between 2000 and 2010, total personal health care expenditures grew from $1.2 trillion to $2.2 trillion (Table 114). During this period, the average annual growth in Medicare expenditures was 9%; for Medicaid it was 7%, for private insurance 6%, and for out-of-pocket spending 4%. In 2010, 34% of personal health care expenditures were paid by private health insurance, 23% by Medicare, 17% by Medicaid, 14% out of pocket, and less than 1% by the Children’s Health Insurance Program (CHIP) (Table 114).

Figure 19 Personal health care expenditures, by source of funds: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2012.htm#fig19

SOURCE: CDC/NCHS, Health, United States, 2012, Table 114. Data from the Centers for Medicare & Medicaid Services, National Health Expenditure Accounts (NHEA).

Figure 19 is a line graph showing trends in personal health care expenditures, by source of funds, for 2000 through 2010.