# Natality

## Teenage Childbearing

Between 2000 and 2010, teenage birth rates declined among all racial and ethnic groups.

In 2010, 3% of births were to teenagers under age 18 and 7% were to mothers aged 18–19 (Table 4). Between 2000 and 2010, birth rates declined 36% for teenagers aged 15–17 and 25% for those aged 18–19 (Table 3). Birth rates were higher among non-Hispanic black and Hispanic teenagers than among other racial and ethnic groups. Since 2000, birth rates have decreased 45% for non-Hispanic black teenagers aged 15–17 and 42% for Hispanic teenagers in the same age group. Also during this period, birth rates for 18–19 year olds decreased 30% for non-Hispanic black teenagers and 32% for Hispanic teenagers.

Figure 5 Teenage childbearing, by maternal age and race and Hispanic origin: United States, 2000 –2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2012.htm#fig05

SOURCE: CDC/NCHS, Health, United States, 2012, Table 3. Data from the National Vital Statistics System (NVSS).

Figure 5 consists of two line graphs, one for mothers aged 15 to 17 and one for mothers aged 18 to 19, showing childbearing rates, by race and Hispanic origin, for 2000 through 2010.