# Morbidity

## Heart Disease Prevalence

During 2000–2001 through 2010–2011, lifetime heart disease prevalence remained stable among men and women in all age groups.

Heart disease is the leading cause of death in the United States for both men and women, accounting for approximately 307,000 deaths for men and 290,000 deaths for women in 2010 (Table 22). During 2000–2001 through 2010–2011, the prevalence of lifetime respondent-reported heart disease among adults aged 18–54 was similar for men and women. Among adults aged 55 and over, heart disease prevalence was higher for men than for women. In 2010–2011, nearly one-half (45%) of men aged 75 and over reported having ever been told by a physician they had heart disease, compared with nearly one-third (31%) of women in the same age group.

Figure 6 Respondent-reported lifetime heart disease prevalence among adults aged 18 and over, by sex and age: United States, average annual, 2000–2001 through 2010–2011

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2012.htm#fig06

SOURCE: CDC/NCHS, Health, United States, 2012, Table 44. Data from the National Health Interview Survey (NHIS).

Figure 6 consists of two line graphs, one for men and one for women, showing respondent-reported lifetime heart disease prevalence among adults aged 18 and over, by age group, for 2000 and 2001 (average annual) through 2010 and 2011 (average annual).