# Health Insurance

## Coverage Among Adults Aged 18–64

During 2001 through 2011, the percentage of adults aged 18–44 and 45–64 with private health insurance coverage decreased, while the percentage with Medicaid coverage and the percentage uninsured increased.

Health insurance is a major determinant of access to health care (14). Among adults aged 18–44, the percentage with private coverage declined from 70% in 2001 to 61% in 2011, while the percentage with Medicaid coverage doubled from 6% to 12%. The percentage of adults aged 18–44 who were uninsured increased from 22% to 25% during the same period. Similarly, between 2001 and 2011, the percentage of adults aged 45–64 with private coverage declined from 79% to 71%; the percentage with Medicaid coverage increased from 5% to 8%; and the percentage uninsured increased from 12% to 15%.

Figure 14 Health insurance coverage among adults aged 18– 64, by age and type of coverage: United States, 2001–2011

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2012.htm#fig14

NOTE: The Medicaid category includes the Children’s Health Insurance Program (CHIP).

SOURCE: CDC/NCHS, Health, United States, 2012, Tables 121, 123, and 124. Data from the National Health Interview Survey (NHIS).

Figure 14 consists of two line graphs, one for adults aged 18 to 44 and one for adults aged 45 to 64, showing health insurance coverage by type of coverage, for 2001 through 2011.

## Coverage Among Adults Aged 19–25

Between 2010 and 2011, the percentage of adults aged 19–25 who were uninsured decreased from 34% to 28%.

Historically, adults aged 19–25 experienced high levels of uninsurance (Table 124). Between 2001 and 2010, the percentage of adults aged 19–25 who were uninsured fluctuated between 31% and 34%, and then decreased from 34% in 2010 to 28% in 2011. The section of the Patient Protection and Affordable Care Act (ACA) that allows most young adults to stay on their parent’s coverage until age 26 came into effect with the policy year that began after September 23, 2010 (15–17). The percentage of adults aged 19–25 with private coverage declined from 59% in 2001 to 52% in 2010 and then rose to 57% in 2011. The percentage with Medicaid coverage [a category that includes the Children’s Health Insurance Program (CHIP)] increased from 8% in 2001 to 13% in 2010 and remained at 13% in 2011.

Figure 15 Health insurance coverage among adults aged 19–25, by type of coverage: United States, 2001–2011

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2012.htm#fig15

SOURCE: CDC/NCHS, Health, United States, 2012, Tables 121, 123, and 124. Data from the National Health Interview Survey (NHIS).

Figure 15 is a line graph showing trends in health insurance coverage among adults aged 19 to 25, by type of coverage, for 2001 through 2011.