# Special Acknowledgment

## EDWARD J. SONDIK

His legacy is well reflected in the success of NCHS’ data collection programs, the advances that have been made in the Nation’s health information system, and most specifically in this enduring assessment of America’s health—Health, United States.

An image of Dr. Edward Sondik.

Health, United States, the annual report on the health of the Nation, has been published by the National Center for Health Statistics (NCHS) for 36 years, and for the past 17 years Dr. Edward J. Sondik, as NCHS Director, has been its strongest supporter. His advocacy has led to wider dissemination in multiple formats and easier access for policy makers and the public alike, thereby expanding its impact. Dr. Sondik advocated using technological advances in publishing to ensure that the information in Health, United States would be utilized by a wider audience and applied to the important health issues of the day. He always highlighted Health, United States in his presentations and relied on findings from Health, United States in major addresses to scientific and statistical audiences. Dr. Sondik was also committed to making the content of the report and each year’s special topic address current and emerging data needs. He knew that a single report claiming to describe the Nation’s health had to be all things to all people and encouraged those involved with its planning, preparation, and production to keep that goal in mind.

Dr. Sondik is retiring this year as NCHS Director after serving in that position longer than any director in NCHS history. His legacy is well reflected in the success of NCHS’ data collection programs, the advances that have been made in the Nation’s health information system, and most specifically in this enduring assessment of America’s health—Health, United States.

An image showing the many editions of Health, United States, produced under Dr. Sondik’s direction.