# Acknowledgments

Overall responsibility for planning and coordinating the content of this volume rested with the National Center for Health Statistics’ (NCHS) Office of Analysis and Epidemiology, under the direction of Julia S. Holmes and Jennifer H. Madans.

Production of Health, United States, 2012, including highlights, trend tables, and appendixes, was managed by Sheila J. Franco, Virginia M. Freid, and Julia S. Holmes. Trend tables were prepared by Mary Ann Bush, Jeanetta E. Churchill, La-Tonya D. Curl, Catherine R. Duran, Sheila J. Franco, Virginia M. Freid, Tamyra C. Garcia, Nancy Han, Ji-Eun Kim, Rashmi Tandon, and Henry Xia, with assistance from Hashini S. Khajuria, Anita L. Powell, Ilene B. Rosen, and Naga Shanmugam. The index was assembled by Anita L. Powell. Review and clearance books were assembled by Ilene B. Rosen. Administrative and word processing assistance was provided by Lillie C. Featherstone and Danielle Wood.

Production of the Chartbook was managed by Sheila J. Franco and Virginia M. Freid. The Special Feature on Emergency Care was prepared and written by Sheila J. Franco. Data and analysis for specific charts were provided by Sheila J. Franco, Virginia M. Freid, and Ji-Eun Kim. Charts were drafted by La-Tonya D. Curl. Technical assistance and programming were provided by Mary Ann Bush, La-Tonya D. Curl, Nancy Han, and Henry Xia.

Publication production was performed by CDC/OSELS/NCHS/OD/Office of Information Services, Information Design and Publishing Staff. Project management and editorial review were provided by Barbara J. Wassell. The graphic design team included Ryan M. Dumas (contractor), Odell D. Eldridge (contractor), Megan Griner, and Kyung M. Park. Layout and production were done by Jacqueline M. Davis and Zung T. Le. Health, United States, 2012: In Brief was produced by Kyung M. Park. Overview for IDPS publications and electronic products was provided by Christine J. Brown, Kimberly N. Ross, and Tommy C. Seibert, Jr. Printing was managed by Nathanael Brown, CDC/OCOO/MASO.

Electronic access through the NCHS website was provided by Christine J. Brown, La-Tonya D. Curl, Jacqueline M. Davis, Virginia M. Freid, Zung T. Le, Anthony Lipphardt, Kyung M. Park, Anita L. Powell, Sharon L. Ramirez, Ilene B. Rosen, Naga Shanmugam, and Barbara J. Wassell.

Data and technical assistance were provided by staff of the following NCHS organizations: Division of Health Care Statistics: Michael Albert, Farida Bhuiya, Carol J. DeFrances, Marni J. Hall, Esther Hing, Maria F. Owings, Susan M. Schappert, Anjali Talwalkar, John Watts, and David Woodwell; Division of Health and Nutrition Examination Surveys: Debra J. Brody, Margaret D. Carroll, Bruce A. Dye, Mark Eberhardt, Jaime J. Gahche, Quiping Gu, Xianfen Li, Cynthia L. Ogden, Ryne Paulose, Chia-Yih Wang, and Sung Sug (Sarah) Yoon; Division of Health Interview Statistics : Patricia F. Adams, Veronica E. Benson, Debra Blackwell, Barbara Bloom, Robin A. Cohen, Whitney Kirzinger, Jacqueline Lucas, Michael Martinez, Jeannine Schiller, Charlotte A. Schoenborn, and Brian W. Ward; Division of Vital Statistics: Joyce C. Abma, Robert N. Anderson, Elizabeth Arias, Anjani Chandra, Brady Hamilton, Melonie Heron, Donna L. Hoyert, Jo Jones, Kenneth D. Kochanek, Angel Liu, Marian MacDorman, Joyce A. Martin, T. J. Mathews, Ari Miniño, Sherry L. Murphy, Michelle Osterman, Betzaida Tejada-Vera, Stephanie J. Ventura, and Elizabeth Wilson; Office of Analysis and Epidemiology: Lara Akinbami, Amy M. Branum, Li-Hui Chen, Catherine R. Duran, Deborah D. Ingram, Laura A. Pratt, and Cheryl V. Rose; Office of the Center Director : Juan Albertorio and Francis C. Notzon; and Office of Research and Methodology: Meena Khare.

Additional data and technical assistance were provided by the following organizations of the Centers for Disease Control and Prevention (CDC): National Center for Chronic Disease Prevention and Health Promotion: Karen Pazol; National Center for HIV/AIDS, Viral Hepatitis, STD, and TB Prevention: Anna S. Johnson, Anne Patala, and Rachel S. Wynn; National Center for Immunization and Respiratory Diseases: Christina Dorell and James A. Singleton; National Institute for Occupational Safety and Health : Roger Rosa; by the following organizations within the Department of Health and Human Services: Agency for Healthcare Research and Quality: Roxanne Andrews, Sadeq Chowdhury, David Kashihara, and Steven R. Machlin; Centers for Medicare & Medicaid Services: Maria Diacogiannis, Micah Hartman, Deborah W. Kidd, Barbara S. Klees, William Long, Maggie S. Murgolo, Jason G. Petroski, Joseph F. Regan, Benjamin E. Washington, and Lekha Whittle; National Institutes of Health: Kathy Cronin, Brenda Edwards, Paul Eggers, Missy Jamison, and Marsha Lopez; Substance Abuse and Mental Health Services Administration: Joe Gfroerer and Beth Han; and by the following governmental and nongovernmental organizations: U.S. Census Bureau: Bernadette D. Proctor; Bureau of Labor Statistics: Christen Byler, Daniel Ginsburg, and Stephen Pegula; Department of Veterans Affairs: Tom Garin, Pheakdey Lim, and Dat Tran; American Association of Colleges of Pharmacy: Jennifer M. Patton, Danielle Taylor, and Maureen Thielemans; American Association of Colleges of Osteopathic Medicine : Wendy Fernando and Tom Levitan; American Association of Colleges of Podiatric Medicine: Moraith G. North; American Osteopathic Association: Margaret Harrison; American Dental Education Association : Adriana R. Menezesa and Brad C. Petersen; Association of American Medical Colleges : Geoffrey Redden; Association of Schools and Colleges of Optometry: Paige Pence and Joanne Zuckerman; Association of Schools of Public Health : Christine Plepys; Cowles Research Group: C. McKeen Cowles; and NOVA Research Company: Shilpa Bengeri.

Thank you!

### Henry Xia

The Health, United States team would like to recognize the long-standing and valuable contributions of Henry Xia, who recently retired from the National Center for Health Statistics. Over the past 15 years, Henry applied his expert computer programming, mathematical, and statistical skills to producing this report. His understanding of complex survey design and methodology enabled him to complete projects of the highest complexity and quality. Henry made significant contributions to Health, United States, was always a pleasure to work with, and was a great member of our team and an esteemed colleague. We extend our heartfelt thanks to Henry for all he accomplished at NCHS—and especially for his work on Health, United States.