# Chartbook With Special Feature on Emergency Care

Chartbook: Figures 1–19

Chartbook: Figures 20–29

Technical Notes