# Chartbook: Figures 20–29

Special Feature on Emergency Care