# At a Glance Table and Highlights

At a Glance Table

Highlights