# Additional Data Years Available

For Trend Tables spanning long periods, only selected data years are shown in Health, United States, to highlight major trends. Additional years of data for some of the Trend Tables are available in electronic spreadsheet form on the Health, United States, 2012, website at: http://www.cdc.gov/nchs/hus.htm. Standard errors are included in the spreadsheet files for tables that are based on the National Health Interview Survey, the National Health and Nutrition Examination Survey, and the National Survey of Family Growth.

Table number | Table topic | Additional data years available
1 | Resident population | 2001–2008
2 | Poverty | 1986–1989, 1991–1994, 1996–1999, 2001–2004, 2006–2009
3 | Fertility rates and birth rates | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2004, 2006
4 | Teenage childbearing | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2004, 2006–2008
5 | Nonmarital childbearing | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2004, 2006–2008
6 | Low birthweight | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2004, 2006–2008
9 | Contraceptive use | 1988
10 | Breastfeeding | 1972–1974
11 | Infant mortality rates | 1996–1999, 2001–2004, 2006
12 | Infant mortality rates | 1984, 1986–1989, 1991, 1996–1999, 2001–2004, 2006
13 | Infant mortality rates | 1981–1989, 1991–1994, 1996–1999, 2001–2002
18 | Life expectancy | 1981–1989, 1991–1994, 1996–1999
20 | Age-adjusted death rates for selected causes | 1981–1989, 1991–1999, 2001–2004, 2006–2008
21 | Years of potential life lost | 1991–1999, 2001–2004, 2006–2008
25 | Death rates for all causes | 1981–1989, 1991–1999, 2001–2008
26 | Diseases of heart | 1981–1989, 1991–1999, 2001–2008
27 | Cerebrovascular diseases | 1981–1989, 1991–1999, 2001–2008
28 | Malignant neoplasms | 1981–1989, 1991–1999, 2001–2008
29 | Malignant neoplasms of trachea, bronchus, and lung | 1981–1989, 1991–1999, 2001–2008
30 | Malignant neoplasm of breast | 1981–1989, 1991–1999, 2001–2008
31 | Human immunodeficiency virus (HIV) disease | 1988–1989, 1991–1994, 2001–2004, 2006–2008
32 | Drug poisoning | 2006–2008
33 | Motor vehicle-related injuries | 1981–1989, 1991–1999, 2001–2008
34 | Homicide | 1981–1989, 1991–1999, 2001–2008
35 | Suicide | 1981–1989, 1991–1999, 2001–2008
36 | Firearm-related injuries | 1981–1989, 1991–1994, 1996–1999, 2001–2004, 2006–2008
37 | Occupational diseases | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2004, 2006–2008
39 | Notifiable diseases | 1985, 1988–1989, 1991–1999, 2001–2007
41 | Health conditions among children | 2006–2008, 2007–2009, 2008–2010
42 | Cancer incidence rates | 1991–1994, 1996–1999, 2001, 2004, 2006
43 | Five-year relative cancer survival rates | 1978–1980, 1984–1986, 1990–1992, 1993–1995, 1996–1998
44 | Respondent-reported prevalence of heart disease, cancer, and stroke | 1999–2000, 2001–2002, 2003–2004, 2005–2006, 2008–2009, 2009–2010
45 | Diabetes | 2001–2004, 2003–2006, 2005–2008
47 | Severe headache or migraine, low back pain, and neck pain | 1998–2009
48 | Basic actions difficulty and complex activity limitation | 1998–1999, 2001–2009
49 | Vision and hearing limitations | 1998–1999, 2001–2009
50 | Respondent-assessed health status | 1998–1999, 2001–2004, 2006–2008
51 | Basic actions difficulty and complex activity limitation | 2008–2010
52 | Basic actions difficulty and complex activity limitation | 2008–2010
53 | Serious psychological distress | 2000–2001, 2002–2003, 2003–2004, 2006–2007, 2007–2008, 2008–2009, 2009–2010
54 | Cigarette smoking | 1983, 1987–1988, 1991–1994, 1997–1999, 2002– 2004, 2006–2009
55 | Cigarette smoking | 1983, 1987–1988, 1991–1994, 1997–1999, 2001– 2004, 2006–2008
56 | Cigarette smoking | 1993–1995, 2006–2008, 2007–2009, 2008–2010
57 | Cigarette smoking | 2008–2010
58 | Use of selected substances | 2003–2008
59 | Use of selected substances | 1981–1984, 1986–1989, 1991–1994, 1996–1999, 2001–2006
61 | Health risk behaviors among students | 1993, 1995, 1997, 1999, 2003, 2005, 2007, 2009
62 | Heavier drinking and drinking five or more drinks in a day | 1998–1999, 2001–2009
64 | Hypertension (high blood pressure) | 2001–2004, 2005–2008
65 | Cholesterol | 2001–2004, 2005–2008
67 | Leisure-time aerobic/muscle-strengthening physical activity | 1999, 2001–2009
68 | Weight and obesity among adults | 2001–2004, 2005–2008
69 | Obesity among children | 2001–2004, 2005–2008
71 | No usual source of health care, children | 1995–1996, 1997–1998, 2001–2002, 2003–2004, 2004–2005, 2005–2006, 2006–2007, 2007–2008, 2008–2009, 2009–2010
72 | No usual source of health care, working-age adults | 2003–2004, 2004–2005, 2005–2006, 2006–2007, 2008–2009, 2009–2010
73 | Reduced access to medical care | 1998–2000, 2002–2009
74 | Reduced access to medical care | 2008–2010
76 | No health care visits | 1999–2000, 2003–2004, 2004–2005, 2005–2006, 2006–2007, 2007–2008, 2008–2009, 2009–2010
77 | Health care visits | 1998–2009
78 | Vaccinations | 1996–1999, 2001–2004
80 | Influenza vaccination | 1991, 1993–1994, 1997–1999, 2001–2004, 2006– 2007
81 | Pneumococcal vaccination among adults | 1991, 1993, 1994, 1997–1999, 2001–2004, 2006– 2007
82 | Mammography | 1991, 1998–1999
83 | Pap smears | 1998, 2003
85 | Emergency department visits for children | 1998–2009
86 | Emergency department visits for adults | 1998–1999, 2001–2009
87 | Injury-related visits to hospital emergency departments | 2008–2009
88 | Ambulatory care visits | 1997–1999, 2001–2008
89 | Ambulatory care visits | 1997–1999, 2001–2009
90 | Dental visits | 1998–2009
91 | Prescription drug use | 2003–2006, 2005–2008
93 | Discharges | 1998–1999, 2001–2009
94 | Discharges | 1991–1994, 1996–1999, 2001–2004, 2006, 2008–2009
95 | Days of care | 1991–1999, 2001–2009
96 | Diagnoses | 1991–1999, 2001–2009
97 | Average length of stay | 1991–1999, 2001–2009
98 | Procedures | 1991–1999, 2001–2009
104 | Health care employment and wages | 2002–2004, 2006–2008, 2010
109 | Nursing homes | 1996–1999, 2001–2009
110 | Medicare-certified providers | 1997–1999, 2001–2003, 2005, 2007, 2009
111 | GDP national health expenditures | 2008
112 | Consumer Price Index | 2007–2009
115 | Cost of hospital discharges | 2006–2009
116 | Expenditures for health care | 1998–1999, 2001–2008
117 | Sources of payment for health care | 1996, 1998–1999, 2001–2008
118 | Out-of-pocket health care expenses | 1998–1999, 2001–2004, 2006–2007
120 | Employers’ costs and health insurance | 1992–1993, 1995, 1997–1999, 2001–2004, 2006– 2007, 2009
121 | Private health insurance | 1994, 1998, 1999, 2002–2004, 2006–2009
122 | Private health insurance, workplace | 1994, 1998, 1999, 2002–2004, 2006–2009
123 | Medicaid coverage | 1994, 1998, 1999, 2002–2004, 2006–2009
124 | No health insurance coverage | 1994, 1998, 1999, 2002–2004, 2006–2009
125 | Health care coverage | 1993–1994, 1996–1999, 2001–2008
127 | Medicare enrollees | 1996–1998, 2001, 2003, 2004, 2006
128 | Medicare beneficiaries | 1999–2007
129 | Medicaid beneficiaries and payments | 2001–2002
130 | Medicaid beneficiaries and payments | 2001–2002
131 | Department of Veterans Affairs | 1985, 1988–1989, 1991–1994, 1996–1999, 2001– 2004, 2006, 2007, 2009
132 | Medicare | 1995–2009
133 | Medicaid | 2001–2008