# Highlights

## Special Feature on Socioeconomic Status and Health

### Children

In 2007–2010, obesity among boys and girls 2–19 years of age decreased with increasing education of the head of household. In households where the head had less than a high school education, 24% of boys and 22% of girls were obese, compared with households where the head had a Bachelor’s degree or higher education in which 11% of boys and 7% of girls were obese (Figure 25).

On average in 2003 and 2007, children 6–11 years of age living below 400% of the poverty level were more likely to have more than 2 hours of screen time on an average weekday (watching TV or videos, playing video games, or using a computer recreationally) (38%–43%) than children living at 400% or more of the poverty level (31%) (Figure 26).

In 2002–2004, babies of mothers who had less than a Bachelor’s degree were less likely to be breastfed for at least 3 months (43%–46%) than babies of mothers who had a Bachelor’s degree or higher education (75%) (Figure 27).

Between 2000 and 2010, the percentage of children with a family income below 200% of the poverty level who were uninsured decreased from 22% to 11%–13%, while the percentage with a family income at 200%–399% of poverty who were uninsured decreased from 9% to 7%, and children with a family income at 400% or more of the poverty level who were uninsured decreased from 3% to 2% (Figure 29).

In 2009–2010, children 5–17 years of age living below 200% of the poverty level were more likely to have been told by a doctor or other health professional that they had attention deficit hyperactivity disorder (11%–13%) than children living at 200% or more of the poverty level (8%) (Figure 24).

In 2010, the percentage of children 2–17 years of age who had a dental visit within the past year rose with relative family income, from 73% of those living below 200% of the poverty level to 88% of those at 400% or more of the poverty level (Figure 30).

### Adults

Between 1996 and 2006, the gap in life expectancy at age 25 between those with less than a high school education and those with a Bachelor’s degree or higher education increased by 1.9 years for men and 2.8 years for women. On average in 2006, 25-year-old men without a high school diploma had a life expectancy 9.3 years less than those with a Bachelor’s degree or higher; women without a high school diploma had a life expectancy 8.6 years less than those with a Bachelor’s degree or higher (Figure 32).

In 2005–2010, the prevalence of depression among adults 45–64 years of age was 5 times as high for those below poverty (24%), 3 times as high for those with family income between 100%–199% of poverty (15%), and more than 1.5 times as high for those with family income between 200%–399% (7%), compared with those at 400% or more of the poverty level (5%) (Figure 33).

In 2010, the percentage of noninstitutionalized adults 18–64 years of age with a disability (defined as a basic actions difficulty or complex activity limitation) was inversely associated with relative family income and was twice as high among those living below the poverty level (40%) compared with those with family income at 400% or more of poverty (20%) (Figure 36).

In 2010, edentulism (lack of natural teeth) was five times as high for adults 45–64 years of age with a family income below 200% of the poverty level (15%) and nearly three times as high for those with family income between 200%–399% of poverty (8%), compared with those at 400% or more of the poverty level (3%) (Figure 34).

In 2007–2010, women 25 years of age and over with less than a Bachelor’s degree were more likely to be obese (39%–43%) than those with a Bachelor’s degree or higher education (25%); obesity among men did not vary consistently by educational attainment (Figure 37).

In 2010, 31% of adults 25–64 years of age with a high school diploma or less education were current smokers, compared with 24% of adults with some college and 9% of adults with a Bachelor’s degree or higher (Figure 38).

In 2010, the percentage of adults 50–75 years of age reporting a colorectal test or procedure increased with increasing education level from 45% among those with no high school diploma to 67% among those with a Bachelor’s degree or higher (Figure 39).

In 2010, adults 18–64 years of age with a family income below 200% of the poverty level were more than six times as likely to be uninsured (42%–43%), and adults with a family income at 200%–399% of the poverty level were three times as likely to be uninsured (21%), as adults with a family income at 400% or more of the poverty level (7%) (Figure 40).

In 2010, about one-quarter of adults 18–64 years of age with a family income below 200% of the poverty level did not get or delayed seeking needed medical care due to cost, compared with 15% of those with a family income at 200%–399% of the poverty level, and 7% of those with a family income at 400% or more of the poverty level (Figure 41).

## Life Expectancy and Mortality

Between 2000 and 2009, life expectancy at birth increased 1.9 years for males and 1.6 years for females. The gap in life expectancy between males and females narrowed from 5.2 years in 2000 to 4.9 years in 2009 (Table 22).

Between 2000 and 2009, life expectancy at birth increased more for the black than for the white population, thereby narrowing the gap in life expectancy between these two racial groups. In 2000, life expectancy at birth for the white population was 5.5 years longer than for the black population. By 2009, the difference had narrowed to 4.3 years (Table 22).

Between 2000 and 2009, the infant mortality rate decreased 7.5%, from 6.91 to 6.39 deaths per 1,000 live births. Infant mortality rates have declined for most racial and ethnic groups, but large disparities among the groups remain (Table 15 and Figure 2).

Between 2000 and 2008, the age-adjusted heart disease death rate decreased 28%, from 257.6 to 186.5 deaths per 100,000 population. In 2008, one-quarter of all deaths were from heart disease (Table 26 and Table 30).

Between 2000 and 2008, the age-adjusted cancer death rate decreased 12%, from 199.6 to 175.3 deaths per 100,000 population. In 2008, 23% of all deaths were from cancer (Table 26 and Table 32).

Between 2000 and 2008, the age-adjusted drug poisoning death rate nearly doubled, increasing from 6.2 to 11.9 deaths per 100,000 population. In 2008, 40% of drug poisoning deaths involved opioid analgesic drugs (Table 36, a new table in the 2011 edition).

## Fertility and Natality

Between 2009 and 2010 (preliminary data), the birth rate among teenagers 15–19 years of age fell 9%, from 37.9 to 34.3 live births per 1,000 females—a record low for the United States (Table 3 and Figure 5).

Low birthweight is associated with elevated risk of death and disability in infants. The percentage of low birthweight births [infants weighing less than 2,500 grams (5.5 pounds) at birth] was 8.15% in 2010 (preliminary data) and has declined slowly since 2006 (8.26%) (Table 9).

## Health Risk Factors

Between 2003 and 2007, the percentage of children 6–11 years of age who did not get daily vigorous physical activity decreased from 69% to 62%; the percentage of children who had more than 2 hours of screen time on an average weekday (watched TV or videos, played video games, or used a computer recreationally) increased from 36% to 40%; and the percentage of children who did not get enough sleep nightly increased from 25% to 28% (Table 66, a new table in the 2011 edition).

Between 1988–1994 and 2009–2010, the prevalence of obesity among preschool-age children 2–5 years of age increased from 7% to 12% (Table 69 and Figure 10).

The prevalence of obesity among school-age children and adolescents increased from 11% to 18% between 1988–1994 and 2009–2010 (Table 69 and Figure 10).

In 2010, 50% of adults 18 years of age and over met neither the aerobic activity nor the muscle-strengthening physical activity federal guidelines. This percentage increased with age, rising from 39% of adults 18–24 years of age to 70% of adults 75 years and over (Table 73).

From 1988–1994 through 2007–2010, the percentage of adults 20 years of age and over with grade 1 obesity [a body mass index (BMI) of 30.0–34.9] increased from 14% to 20%. Those with grade 2 obesity (BMI of 35.0–39.9) nearly doubled, from 5% to 9%, and those with grade 3 or higher obesity (BMI of 40 or higher) rose from 3% to 6% (Table 74).

In 2010, 19% of U.S. adults were current cigarette smokers, a decline from 21% in 2009. Men were more likely than women to be current cigarette smokers (Table 60 and Figure 8).

## Measures of Health and Disease Prevalence

In 2008–2010, 6% of children under 18 years of age had an asthma attack in the past year, 12% had a skin allergy, and 6% had three or more ear infections in the past year. Among school-age children 5–17 years of age, 9% had attention deficit hyperactivity disorder and 6% had serious emotional or behavioral difficulties (Table 46).

In 2010, the percentage of noninstitutionalized adults who reported their health as fair or poor ranged from 6% of those 18–44 years of age to 28% of those 75 years and over (Table 56).

In 2010, 27% of noninstitutionalized adults 18–64 years of age reported a disability (defined as any basic actions difficulty or complex activity limitation), compared with 62% of those 65 years of age and over (Table 54).

In 2009–2010, 45% of men and 31% of women 75 years of age and over had ever been told by a physician or other health professional that they had heart disease. Among those 75 years of age and over, heart disease prevalence rose between 1999–2000 and 2009–2010 among men but not among women (Table 49).

In 2009–2010, 25% of men and 18% of women 75 years of age and over had ever been told by a physician or other health professional that they had cancer (excluding squamous and basal cell skin cancers) (Table 49).

Between 1988–1994 and 2007–2010, the prevalence of uncontrolled high blood pressure among adults 20 years of age and over with hypertension decreased from 74% to 49% (Table 70).

Between 1988–1994 and 2007–2010, the percentage of adults 20 years of age and over with a high serum total cholesterol level (defined as greater than or equal to 240 mg/dL) declined from 20% to 14% (Table 71).

## Health Care Utilization

### Use of Health Care Services

In 2009, there were 1.3 billion visits to physician offices, hospital outpatient departments, and hospital emergency departments. Of these, 1.0 billion were visits to physician offices, 96 million were visits to hospital outpatient departments, and 136 million were visits to hospital emergency departments (Table 96).

In 2010, 21% of adults 18 years of age and over had one or more emergency department visits in the past year, and 8% had two or more visits. (Table 94).

In 2010, 79% of children 2–17 years of age, 61% of adults 18–64 years, and 58% of adults 65 years of age and over had seen a dentist in the past year (Table 98).

Between 2000 and 2008–2009, the nonfederal short-stay hospital discharge rate was stable at 1,100–1,200 discharges per 10,000 population, and the average length of stay was 5 days (Table 103).

The percentage of the population taking at least one prescription drug during the past 30 days increased from 38% in 1988–1994 to 48% in 2005–2008. During the same period, the percentage taking three or more prescription drugs nearly doubled, from 11% to 21%, and the percentage taking five or more drugs increased from 4% to 11% (Table 99).

### Use of Preventive Medical Care Services

In 2010, one-half of noninstitutionalized adults 50 years of age and over had received influenza vaccination in the past year, ranging from 42% of those 50–64 years of age to 68% of those 75 years of age and over (Table 88 and Figure 12).

Between 2000 and 2010, the percentage of noninstitutionalized adults 65 years of age and over who ever received a pneumococcal vaccination increased from 53% to 60%. In 2010, 55% of those 65–74 years of age and 66% of those 75 years of age and over ever had a pneumococcal vaccination (Table 89 and Figure 12).

The percentage of women 40 years of age and over who had a mammogram in the past 2 years ranged from 67% to 70% between 2000 and 2010 (Table 90).

The percentage of adults 50–75 years of age with any colorectal test or procedure increased from 34% in 2000 to 59% in 2010. The percentage of adults 50–75 years of age reporting a colonoscopy procedure nearly tripled from 2000 to 2010, increasing from 19% to 55% (Table 92, a new table in the 2011 edition; and Figure 39).

## Urbanization Level: Health Status, Risk Factors, and Access to Care

In 2008–2010, the percentage of adults 18–64 years of age with disability (defined as any basic actions difficulty or complex activity limitation) was lower in large central metropolitan counties compared with the most rural nonmetropolitan counties. The percentage of adults 18–64 years of age with a disability ranged from 23%–25% in the most urban (large central and large fringe) metropolitan counties to 36% in the most rural (nonmicropolitan) counties (Table 57, a new table in the 2011 edition).

In 2008–2010, the percentage of adults 18–64 years of age who were current cigarette smokers was generally lower in more urban (large central and large fringe) metropolitan counties (19%–21%) compared with nonmetropolitan counties (28%–30%) (Table 63, a new table in the 2011 edition).

In 2008–2010, the percentage of adults 18–64 years of age who reported not receiving or delaying seeking needed medical care due to cost in the past year was lowest in large fringe metropolitan counties (12%), compared with large central metropolitan counties (14%), medium and small metropolitan counties (15%), and nonmetropolitan counties (17%) (Table 80, a new table in the 2011 edition).

In 2008–2010, the percentage of adults 18–64 years of age living in large fringe metropolitan counties who were uninsured (17%) was lower than in counties of other urbanization levels (21%–25%), although the pattern differed among the four regions of the country. For example, in the West region, the percentage of adults who were uninsured was 19% in the large fringe metropolitan counties compared with 24% in other metropolitan counties and 27%–33% in nonmetropolitan counties (Table 80, a new table in the 2011 edition).

## Unmet Need for Medical Care, Prescription Drugs, and Dental Care Due to Cost

Between 1997 and 2010, among adults 18–64 years of age, the percentage who reported not receiving or delaying seeking needed medical care due to cost in the past 12 months increased from 11% to 15%; the percentage not receiving needed prescription drugs due to cost nearly doubled, rising from 6% to 11%; and the percentage not receiving needed dental care due to cost grew from 11% to 17% (Table 79).

In 2010, 35% of adults 18–64 years of age who were uninsured did not get or delayed seeking needed medical care due to cost in the past 12 months, compared with 8% of adults with private coverage and 13% of adults with Medicaid (Table 79 and Figure 18).

In 2010, 26% of adults 18–64 years of age who were uninsured did not get needed prescription drugs due to cost in the past 12 months, compared with 6% of those with private coverage and 14% of those with Medicaid (Table 79 and Figure 18).

## Health Care Resources

Between 2000 and 2009, the number of physicians in patient care increased 12%, from 23 to 25 per 10,000 population. In 2009, the number of patient care physicians per 10,000 population ranged from 17 in Idaho and Mississippi to 40 in Massachusetts (Table 109 and Figure 19).

Between 2000 and 2009, there were about 5,000 community hospitals and 800,000 community hospital beds (Table 116).

In 2010, there were about 1.7 million nursing home beds in 16,000 certified nursing homes. Between 2000 and 2010, nursing home bed occupancy for the United States was stable at 82% (Table 120).

## Health Care Expenditures and Payers

### Health Care Expenditures

In 2009, national health care expenditures in the United States totaled $2.5 trillion, a 4% increase from 2008. The average per capita expenditure on health was $8,000 in 2009 (Table 125 and Table 128).

Expenditures for hospital care accounted for 31% of all national health expenditures in 2009. Physician and clinical services accounted for 20% of the total, prescription drugs for 10%, and nursing care facilities and continuing care retirement communities for 6% (Table 128).

Prescription drug expenditures increased 5.3% between 2008 and 2009, compared with a 3.1% increase between 2007 and 2008 (Table 128).

In 2009, the average cost for the entire hospitalization involving a heart valve procedure was $49,000, a coronary artery bypass graft procedure was $36,000, cardiac pacemaker insertion or replacement was $33,000, and spinal fusion was $26,000 (Table 132, a new table in the 2011 edition).

### Health Care Payers

In 2009, 34% of personal health care expenditures were paid by private health insurance; consumers paid 14% out of pocket; 23% was paid by Medicare and 17% by Medicaid; and the remainder was paid by other insurance, payers, and programs (Table 129 and Figure 20).

In 2010, the Medicare program had 48 million enrollees and expenditures of $523 billion, up from $509 billion the previous year. Expenditures for the Medicare drug program (Part D) were $62 billion in 2010 (Table 143).

Of the 35 million Medicare enrollees in the fee-for-service program in 2009, 18% were under 65 years of age, compared with 15% in 2000 (Table 144).

In 2009, children under 21 years of age accounted for 48% of Medicaid recipients but only 20% of expenditures. Aged, blind, and persons with disabilities accounted for 21% of recipients and 63% of expenditures (Table 146).

In 2009, the Children’s Health Insurance Program (CHIP) accounted for $9.5 billion (less than 1%) of personal health care expenditures (Table 129).

## Health Insurance Coverage

Between 2000 and 2010, the percentage of the population under 65 years of age with private health insurance obtained through the workplace declined from 67% to 57% (Table 139).

In 2010, 8% of children under 18 years of age and 22% of adults 18–64 years of age had no health insurance coverage (public or private) at the time of interview (Table 141).

Between 2000 and 2010, among children in families with income just above the poverty level (100%–199% of poverty), the percentage of uninsured children under 18 years of age dropped from 22% to 13%, while the percentage with coverage through Medicaid or the Children’s Health Insurance Program (CHIP) increased from 28% to 54% (Table 140 and Table 141).