# Acknowledgments

Overall responsibility for planning and coordinating the content of this volume rested with the National Center for Health Statistics’ (NCHS) Office of Analysis and Epidemiology, under the direction of Amy B. Bernstein, Diane M. Makuc, and Linda T. Bilheimer.

Production of Health, United States, 2011, including highlights, trend tables, and appendixes, was managed by Amy B. Bernstein, Sheila J. Franco, and Virginia M. Freid. Trend tables were prepared by Mary Ann Bush, Jeanetta E. Churchill, La-Tonya D. Curl, Anne K. Driscoll, Catherine R. Duran, Sheila J. Franco, Virginia M. Freid, Tamyra C. Garcia, Nancy Han, Ji-Eun Kim, Rebecca A. Placek, and Henry Xia, with assistance from Anita L. Powell and Ilene B. Rosen. Appendix II tables and the index were assembled by Anita L. Powell. Production planning and coordination of trend tables were managed by Rebecca A. Placek. Review and clearance books were assembled by Ilene B. Rosen. Administrative and word processing assistance was provided by Lillie C. Featherstone and Danielle Wood.

Production of the Chartbook was managed by Virginia M. Freid and Sheila J. Franco. Data and analysis for specific charts were provided by Amy B. Bernstein, Anne K. Driscoll, Sheila J. Franco, Virginia M. Freid, Tamyra C. Garcia, Ji-Eun Kim, Kimberly Lochner, and Elsie Pamuk. Charts were drafted by La-Tonya D. Curl, and data tables were prepared by Rebecca A. Placek. Technical assistance and programming were provided by Mary Ann Bush, La-Tonya D. Curl, Catherine R. Duran, Nancy Han, Xiang Liu, and Henry Xia.

Publication production was performed by CDC/OSELS/NCHS/OD/Office of Information Services, Information Design and Publishing Staff. Project management and editorial review were provided by Barbara J. Wassell. The designer was Sarah M. Hinkle. The cover was designed by Megan Griner. Layout and production were done by Zung T. Le and Jacqueline M. Davis. Design and production for Health, United States, 2011: In Brief were provided by Kyung M. Park. Oversight review for publications and electronic products was provided by Christine J. Brown, Tommy C. Seibert, Jr., and Tammy Stewart-Prather. Printing was managed by Patricia L. Wilson, CDC/OCOO/MASO.

Electronic access through the NCHS Internet site was provided by Christine J. Brown, La-Tonya D. Curl, Jacqueline M. Davis, Zung T. Le, Anthony Lipphardt, Anita L. Powell, Sharon L. Ramirez, Ilene B. Rosen, and Barbara J. Wassell.

Data and technical assistance were provided by staff of the following NCHS organizations: Division of Health Care Statistics: Vladislav Beresovsky, Frederic H. Decker, Carol J. DeFrances, Lisa L. Dwyer, Marni J. Hall, Lauren Harris-Kojetin, Maria F. Owings, and Susan M. Schappert; Division of Health and Nutrition Examination Surveys: Debra J. Brody, Margaret D. Carroll, Bruce A. Dye, Mark Eberhardt, Jaime J. Gahche, Quiping Gu, Xianfen Li, Cynthia L. Ogden, Ryne Paulose, Sung Sug (Sarah) Yoon, and Chia-Yih Wang; Division of Health Interview Statistics: Patricia F. Adams, Veronica E. Benson, Barbara Bloom, Robin A. Cohen, Susan S. Jack, Whitney Kirzinger, Jacqueline Lucas, Michael Martinez, Kathleen S. O’Connor, Jennifer Peregoy, Jeannine Schiller, Charlotte A. Schoenborn, and Brian W. Ward; Division of Vital Statistics: Joyce C. Abma, Robert N. Anderson, Elizabeth Arias, Anjani Chandra, Brady Hamilton, Donna L. Hoyert, Kenneth D. Kochanek, Marian MacDorman, Joyce A. Martin, T. J. Mathews, Ari Miniño, Sherry L. Murphy, Michelle Osterman, and Stephanie J. Ventura; Office of Analysis and Epidemiology: Lara Akinbami, Li-Hui Chen, Deborah D. Ingram, Susan Lukacs, Patricia Pastor, Laura A. Pratt, Kenneth Schoendorf, Cynthia A. Reuben, Cheryl V. Rose, Rashmi Tandon, Margaret Warner, and Julie Dawson Weeks; Office of the Center Director: Juan Albertorio and Francis C. Notzon; and Office of Research and Methodology: Meena Khare.

Additional data and technical assistance were provided by the following organizations of the Centers for Disease Control and Prevention (CDC): Epidemiology Program Office: Samuel L. Groseclose and Michael Wodajo; National Center for Chronic Disease Prevention and Health Promotion: Sonya Gamble, Steve Kinchen, and Karen Pazol; National Center for HIV/AIDS, Viral Hepatitis, STD, and TB Prevention: Stacy Cohen, Irene Hall, Alexis Kaigler, Rachel S. Wynn, and Jill Wasserman; National Center for Immunization and Respiratory Diseases: Christina Dorell and James A. Singleton; National Institute for Occupational Safety and Health: John Myers, Kara Perritt, Roger Rosa, and John Sestito; by the following organizations within the Department of Health and Human Services: Agency for Healthcare Research and Quality: Roxanne Andrews, David Kashihara, and Steven R. Machlin; Centers for Medicare & Medicaid Services: Joseph Benson, M. Kent Clemens, Cathy A. Cowan, Christine Cox, Maria Diacogiannis, Micah Hartman, Stephanie L. Hunt, Christopher Kessler, Deborah W. Kidd, Barbara S. Klees, John Klemm, Kimberly Lochner, Maggie S. Murgolo, Jason G. Petroski, Joseph F. Regan, Thomas W. Reilly, Loan Swisher, John A. Wandishin, Benjamin E. Washington, Lekha Whittle, and Lirong Zhao; National Institutes of Health: Nancy Breen, Kathy Cronin, Brenda Edwards, Paul W. Eggars, and Marsha Lopez; Substance Abuse and Mental Health Services Administration: Jeffrey Buck, James Colliver, Joe Gfroerer, Beth Han, Laura Milazzo-Sayre, and Rita Vandivort-Warren; and by the following governmental and nongovernmental organizations: U.S. Census Bureau: Bernadette D. Proctor; Bureau of Labor Statistics: Daniel Ginsburg, Jeffrey Schildkraut, Stephen Pegula, Elizabeth Rogers, and Audrey Watson; Department of Veterans Affairs: Pheakdey Lim and Dat Tran; American Association of Colleges of Pharmacy: Jennifer M. Patton, Danielle Taylor, and Maureen Thielemans; American Association of Colleges of Osteopathic Medicine: Wendy Fernando and Tom Levitan; American Association of Colleges of Podiatric Medicine: Moraith G. North; American Osteopathic Association: Margaret Harrison; American Dental Education Association: Jon D. Ruesch; Association of American Medical Colleges: Franc Slapar and Amber Sterling; Association of Schools and Colleges of Optometry: Paige Pence and Joanne Zuckerman; Association of Schools of Public Health: Kristin Dolinski; Cowles Research Group: C. McKeen Cowles; NOVA Research Company: Shilpa Bengeri; and Thomson Reuters: Rosanna Coffey and Katharine Levit.

SPECIAL ACKNOWLEDGMENTS

Dr. Diane Makuc

and

Ms. Rebecca Placek

All those associated with Health, United States would like to give special thanks to Dr. Diane Makuc and Ms. Rebecca Placek, who recently retired from the National Center for Health Statistics.

Dr. Makuc contributed to Health, United States for more than 30 years, providing direction and insightful guidance for the report. Her strong grasp of public health issues, knowledge of NCHS data systems, and expertise in statistical methodology were key to ensuring the high quality and continued relevance of this annual report to Congress on the health of the Nation.

For 32 years, Ms. Placek was the anchor of the Health, United States production team—keeping this large and complex project well organized and of the highest quality. She managed the entire trend table production process with a wonderful combination of meticulousness and good spirits, and was instrumental in designing systems to track the overall production status of the report.

The Health, United States team is truly grateful to both Diane and Becky for their vital and tireless contributions to the report over their many years of association. We miss them dearly and wish them the very best in their retirement!