# Data Tables for Special Feature: Figures 22–41

## Children

Data table for Figure 22 Children under 18 years of age, by percent of poverty level and race and Hispanic origin: United States, 1990–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig22

| | Race and Hispanic origin
Characteristic | All children | Hispanic | White, not Hispanic | Black | Asian
Year | Percent below poverty
1990 | 20.6 | 38.4 | 12.3 | 44.8 | 17.6
1991 | 21.8 | 40.4 | 13.1 | 45.9 | 17.5
1992 | 22.3 | 40.0 | 13.2 | 46.6 | 16.4
1993 | 22.7 | 40.9 | 13.6 | 46.1 | 18.2
1994 | 21.8 | 41.5 | 12.5 | 43.8 | 18.3
1995 | 20.8 | 40.0 | 11.2 | 41.9 | 19.5
1996 | 20.5 | 40.3 | 11.1 | 39.9 | 19.5
1997 | 19.9 | 36.8 | 11.4 | 37.2 | 20.3
1998 | 18.9 | 34.4 | 10.6 | 36.7 | 18.0
1999 | 17.1 | 30.3 | 9.4 | 33.2 | 11.9
2000 | 16.2 | 28.4 | 9.1 | 31.2 | 12.7
2001 | 16.3 | 28.0 | 9.5 | 30.2 | 11.5
2002 | 16.7 | 28.6 | 9.4 | 32.3 | 11.7
2003 | 17.6 | 29.7 | 9.8 | 34.1 | 12.5
2004 | 17.8 | 28.9 | 10.5 | 33.7 | 9.9
2005 | 17.6 | 28.3 | 10.0 | 34.5 | 11.1
2006 | 17.4 | 26.9 | 10.0 | 33.4 | 12.2
2007 | 18.0 | 28.6 | 10.1 | 34.5 | 12.5
2008 | 19.0 | 30.6 | 10.6 | 34.7 | 14.6
2009 | 20.7 | 33.1 | 11.9 | 35.7 | 14.0
2010 | 22.0 | 35.0 | 12.4 | 39.1 | 14.4
Percent of poverty level, 2010 | Percent distribution
Total | 100.0% | 100.0% | 100.0% | 100.0% | 100.0%
Below 100% | 22.0 | 35.0 | 12.4 | 39.1 | 14.4
100%–199% | 21.6 | 30.0 | 16.8 | 25.9 | 18.9
200%–399% | 29.4 | 24.4 | 33.5 | 23.5 | 26.8
400% or more | 27.0 | 10.5 | 37.3 | 11.4 | 39.9

NOTES: Persons of Hispanic origin may be of any race. Prior to 2002, estimates included persons who reported more than one race. Starting in 2002, estimates are for persons who reported a single race. Also starting in 2002, the category Asian and Pacific Islander was changed to Asian. Percent distribution may not total to 100% because of rounding.

SOURCE: U.S. Census Bureau, Current Population Survey, Annual Social and Economic (ASEC) Supplement: http://www.census.gov/hhes/www/cpstables/032011/pov/new01_000.htm and http://www.census.gov/hhes/www/poverty/data/historical/people.html.

Data table for Figure 23 Current asthma among children under 18 years of age, by race and Hispanic origin and percent of poverty level: United States, 2009–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig23

Race and Hispanic origin and percent of poverty level | Percent | SE
All children | 9.5 | 0.3
Below 100% | 12.8 | 0.7
100%–199% | 9.8 | 0.6
200%–399% | 8.0 | 0.4
400% or more | 8.2 | 0.4
Hispanic | 7.9 | 0.4
Below 100% | 8.4 | 0.8
100%–199% | 7.2 | 0.8
200%–399% | 7.7 | 0.9
400% or more | 8.8 | 1.4
Mexican origin | 6.7 | 0.5
Below 100% | 6.3 | 0.8
100%–199% | 5.9 | 0.9
200%–399% | 8.1 | 1.2
400% or more | *9.1 | 2.0
Puerto Rican origin | 17.7 | 1.9
Below 100% | 25.8 | 3.8
100%–199% | *17.5 | 3.7
200%–399% | *10.9 | 2.8
400% or more | * | *
White only, not Hispanic | 8.4 | 0.3
Below 100% | 12.2 | 1.4
100%–199% | 9.6 | 0.9
200%–399% | 6.9 | 0.5
400% or more | 7.8 | 0.5
Black or African American only, not Hispanic | 16.4 | 0.9
Below 100% | 20.9 | 1.6
100%–199% | 15.0 | 1.6
200%–399% | 12.6 | 1.3
400% or more | 13.1 | 1.8
Asian only | 8.1 | 1.0
Below 100% | * | *
100%–199% | * | *
200%–399% | *8.4 | 2.2
400% or more | *9.1 | 1.9

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error (RSE) of 20%–30%. Data not shown have an RSE of greater than 30%.

NOTES: SE is standard error. Data are for the civilian noninstitutionalized population. Current asthma is based on a parent or knowledgeable adult responding to both questions: “Has a doctor or other health professional ever told you that your child had asthma?” and “Does your child still have asthma?” Persons of Hispanic origin may be of any race. Asian race includes persons of both Hispanic and non-Hispanic origin. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Missing family income data were imputed for 2009–2010. See Appendix II, Family income; Hispanic origin; Poverty; Race; Table VI. Also see Table 46.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Data table for Figure 24 Attention deficit hyperactivity disorder among children 5–17 years of age, by race and Hispanic origin and percent of poverty level: United States, 2009–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig24

Race and Hispanic origin and percent of poverty level | Percent | SE
All children | 9.6 | 0.3
Below 100% | 12.6 | 0.7
100%–199% | 10.7 | 0.8
200%–399% | 8.2 | 0.5
400% or more | 8.0 | 0.5
Hispanic | 5.1 | 0.4
Below 100% | 5.8 | 1.0
100%–199% | 4.9 | 0.7
200%–399% | 3.9 | 0.7
400% or more | 5.8 | 1.1
White only, not Hispanic | 11.2 | 0.4
Below 100% | 18.2 | 1.7
100%–199% | 14.9 | 1.5
200%–399% | 9.7 | 0.7
400% or more | 8.8 | 0.6
Black or African American only, not Hispanic | 11.6 | 0.7
Below 100% | 16.5 | 1.6
100%–199% | 10.3 | 1.6
200%–399% | 8.3 | 1.2
400% or more | *6.9 | 1.4
Asian only | *1.2 | 0.3
Below 100% | * | *
100%–199% | * | *
200%–399% | * | *
400% or more | * | *

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error (RSE) of 20%–30%. Data not shown have an RSE of greater than 30%.

NOTES: SE is standard error. Data are for the civilian noninstitutionalized population. Based on a parent or knowledgeable adult responding to the question: “Has a doctor or health professional ever told you that your child has attention deficit hyperactivity disorder (ADHD) or attention deficit disorder (ADD)?” Persons of Hispanic origin may be of any race. Asian race includes persons of both Hispanic and non-Hispanic origin. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Missing family income data were imputed for 2009–2010. See Appendix II, Family income; Hispanic origin; Poverty; Race; Table VI. Also see Table 46.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Data table for Figure 25 Obesity among children 2–19 years of age, by sex of child and education level of head of household: United States, 1988–1994 and 2007–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig25

Sex of child and education level of household head | 1988–1994 | | 2007–2010
Sex of child and education level of household head
Sex of child and education level of household head | Percent | SE | Percent | SE
Boys 2–19 years | 10.2 | 0.7 | 18.2 | 0.9
Household head
No high school diploma | 15.3 | 1.6 | 24.0 | 1.7
High school graduate or GED | 11.0 | 1.3 | 19.0 | 1.3
Some college | 9.3 | 1.8 | 18.1 | 1.6
Bachelor’s degree or higher | * | * | 11.4 | 1.7
Girls 2–19 years | 9.8 | 0.8 | 15.4 | 0.9
Household head
No high school diploma | 11.3 | 1.3 | 22.3 | 2.1
High school graduate or GED | 12.1 | 1.5 | 20.6 | 2.5
Some college | *8.6 | 2.0 | 14.1 | 1.4
Bachelor’s degree or higher | *5.4 | 1.5 | 7.1 | 1.1

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error (RSE) of 20%–30%. Data not shown have an RSE of greater than 30%.

NOTES: SE is standard error; GED is General Educational Development high school equivalency diploma. Data are for the civilian noninstitutionalized population. Totals include those with unknown education for the head of household. Obesity is body mass index (BMI) at or above the sex-and age-specific 95th percentile BMI cutoff points from the 2000 CDC Growth Charts: United States. Kuczmarski RJ, Ogden CL, Guo SS, Grummer-Strawn LM, Flegal KM, Mei Z, et al. 2000 CDC Growth Charts for the United States: Methods and development. Vital Health Stat 2002 May;11(246):1–190. Available from: http://www.cdc.gov/nchs/data/series/sr_11/sr11_246.pdf. In 1988–1994, respondents were asked about the household head, “What is the highest grade or year of regular school PERSON has completed?” In 2007–2010, respondents were asked about the household head, “What is the highest grade or level of school (you have/PERSON has) completed or the highest degree (you have/PERSON has) received?” Estimates exclude pregnant women. See Appendix II, Body mass index (BMI); Education. Also see Table 75.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey. See Appendix I, National Health and Nutrition Examination Survey (NHANES).

Data table for Figure 26 Children 6–11 years of age who engaged in more than 2 hours of screen time daily, by sex and percent of poverty level: United States, average annual, 2003 and 2007

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig26

Sex and percent of poverty level | Percent | SE
6–11 years
Below 100% | 41.1 | 1.2
100%–199% | 43.0 | 1.0
200%–399% | 38.4 | 0.8
400% or more | 31.1 | 0.8
Boys 6–11 years
Below 100% | 41.1 | 1.6
100%–199% | 43.7 | 1.4
200%–399% | 39.1 | 1.1
400% or more | 31.0 | 1.0
Girls 6–11 years
Below 100% | 41.3 | 1.8
100%–199% | 42.4 | 1.4
200%–399% | 37.8 | 1.1
400% or more | 31.1 | 1.2

NOTES: SE is standard error. Data are for the civilian noninstitutionalized population. Totals include those with gender not stated. Screen time includes watching TV or videos, playing video games, or using a computer for non-school-related activities. Respondents were asked, “On an average weekday, about how much time does CHILD use a computer for purposes other than schoolwork?” and “On an average weekday, about how much time does CHILD usually watch TV, watch videos, or play video games?” Responses from these two questions were combined to create the screen time measure. Percent of poverty level is based on family income and family composition using U.S. Census Bureau poverty thresholds. The poverty categories available in the two survey years used slightly different cut points. In 2003, the available categories were: Below 100%, 100%–199%, 200%–399%, and 400% or more. In 2007, the poverty categories were: At/below 100%, 101%–200%, 201%–400%, and Above 400%. Missing family income data were imputed. See Appendix II, Family income; Poverty. Also see Table 66.

SOURCE: CDC/NCHS, State and Local Area Integrated Telephone Survey, National Survey of Children’s Health. See Appendix I, National Survey of Children’s Health (NSCH).

Data table for Figure 27 Babies breastfed 3 months or more among mothers 22–44 years of age, by mother’s education level: United States, 1992–1994 through 2002–2004

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig27

| 1992–1994 | | 1995–1998 | | 1999–2001 | | 2002–2004
Mother’s education level | Percent | SE | Percent | SE | Percent | SE | Percent | SE
Mothers 22–44 years | 33.6 | 1.2 | 45.8 | 1.7 | 48.4 | 1.9 | 53.2 | 2.6
No high school diploma | 25.2 | 3.1 | 33.9 | 3.3 | 37.0 | 4.4 | 45.8 | 8.9
High school graduate or GED | 27.4 | 2.2 | 36.9 | 3.9 | 43.1 | 3.3 | 43.2 | 4.1
Some college | 38.7 | 2.8 | 49.6 | 2.9 | 52.8 | 3.0 | 43.7 | 4.3
Bachelor’s degree or higher | 59.3 | 2.5 | 64.5 | 3.3 | 64.1 | 3.7 | 74.6 | 3.7

NOTES: SE is standard error; GED is General Educational Development high school equivalency diploma. Data are for the civilian noninstitutionalized population. Mother’s education is at time of interview. Data are based on single births to mothers 22–44 years of age at time of interview and may include births that occurred when the mothers were younger than 22 years of age. The American Academy of Pediatrics recommends exclusive breastfeeding for the first 6 months of life. This analysis was limited to breastfeeding for the first 3 months of life in order to have sufficient numbers to analyze breastfeeding practices by mother’s education level. Estimates for the percentage of babies breastfed 3 or more months are based on the questions: “When [child] was an infant, have/did you breastfed him/her at all?” and “How old was he/she when you stopped breastfeeding him/her altogether?” Babies with mothers who responded yes to the first question and reported that they stopped breastfeeding their child altogether at 3 or more months, or the equivalent of 3 or more months in weeks or in days, are classified as being breastfed 3 or more months. See Appendix II, Education. Also see Table 14.

SOURCE: CDC/NCHS, National Survey of Family Growth, Cycle 5 conducted in 1995 (1992–1994), Cycle 6 conducted in 2002 (1995–1998 and 1999–2001), and Cycle 7 conducted in 2006–2008 (2002–2004). See Appendix I, National Survey of Family Growth (NSFG).

Data table for Figure 28 Vaccinations among adolescents 13–17 years of age, by type of vaccine and percent of poverty level: United States, 2009

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig28

| | | Percent of poverty level
| Total 13–17 years | | Below 100% | | 100%–199% | | 200%–399% | | 400% or more
Vaccination | Percent | SE | Percent | SE | Percent | SE | Percent | SE | Percent | SE
Measles, mumps, rubella (MMR) (2 doses or more) | 89.1 | 0.4 | 87.8 | 1.1 | 86.9 | 1.0 | 88.6 | 0.8 | 91.8 | 0.6
Hepatitis B (Hep B) (3 doses or more) | 89.9 | 0.4 | 88.3 | 1.0 | 88.7 | 0.9 | 90.0 | 0.7 | 91.5 | 0.6
History of varicella disease or received varicella vaccine (2 doses or more) | 75.7 | 0.6 | 74.4 | 1.6 | 72.6 | 1.4 | 76.0 | 1.0 | 78.1 | 0.8
Tetanus and diphtheria toxoids and acellular pertussis (Tdap) (1 dose or more since age 10) | 55.6 | 0.6 | 52.8 | 1.8 | 49.9 | 1.6 | 57.8 | 1.1 | 58.4 | 1.0
Meningococcal conjugate vaccine (MenACWY) (1 dose or more) | 53.6 | 0.6 | 52.5 | 1.8 | 48.6 | 1.6 | 50.2 | 1.1 | 60.9 | 1.0
Human papillomavirus (HPV) (3 doses or more, reported among females) | 26.7 | 0.8 | 25.5 | 2.2 | 23.9 | 1.9 | 22.8 | 1.3 | 32.3 | 1.3

NOTES: SE is standard error. Data are for the civilian noninstitutionalized population. Varicella is chickenpox. For meningococcal vaccine, includes persons receiving MenACWY or meningococcal-unknown type vaccine. Information on the adolescent vaccination schedule is available from: http://www.cdc.gov/vaccines/recs/schedules/downloads/child/mmwr-child-schedule.pdf. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Missing family income data were imputed. See Appendix II, Family income; Poverty; Vaccination. Also see Table 87.

SOURCE: CDC/NCHS, and National Center for Immunization and Respiratory Diseases, National Immunization Survey (NIS)– Teen. See Appendix I, National Immunization Survey (NIS).

Data table for Figure 29 No health insurance coverage among children under 18 years of age, by percent of poverty level and race and Hispanic origin: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig29

Characteristic | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 2008 | 2009 | 2010
Percent of poverty level | Percent
Under 18 years | 12.6 | 11.2 | 10.9 | 9.8 | 9.2 | 9.3 | 9.5 | 9.0 | 9.0 | 8.2 | 7.8
Below 100% | 22.0 | 20.7 | 17.0 | 16.8 | 15.0 | 14.3 | 13.9 | 11.9 | 13.3 | 11.8 | 10.6
100%–199% | 21.7 | 18.6 | 17.0 | 15.6 | 15.1 | 15.0 | 16.0 | 15.7 | 15.5 | 12.3 | 12.7
200%–399% | 9.3 | 8.3 | 9.4 | 8.1 | 7.6 | 7.8 | 7.4 | 8.2 | 7.5 | 7.8 | 7.0
400% or more | 3.3 | 3.2 | 3.7 | 2.7 | 2.6 | 3.2 | 3.1 | 2.2 | 2.7 | 2.3 | 2.1
| SE
Under 18 years | 0.3 | 0.4 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4 | 0.3
Below 100% | 1.0 | 1.1 | 0.9 | 1.0 | 1.0 | 0.8 | 0.9 | 1.0 | 1.0 | 0.8 | 0.9
100%–199% | 0.9 | 0.8 | 0.8 | 0.8 | 0.8 | 0.8 | 0.9 | 1.0 | 0.9 | 0.8 | 0.7
200%–399% | 0.6 | 0.5 | 0.7 | 0.6 | 0.5 | 0.5 | 0.6 | 0.6 | 0.7 | 0.7 | 0.5
400% or more | 0.3 | 0.5 | 0.4 | 0.3 | 0.3 | 0.3 | 0.4 | 0.3 | 0.4 | 0.3 | 0.3
Race and Hispanic origin and percent of poverty level, 2009–2010 | Percent | | | SE
Hispanic | | 13.8 | | | 0.5
Below 100% | | 15.0 | | | 0.9
100%–199% | | 16.8 | | | 0.9
200%–399% | | 12.0 | | | 1.0
400% or more | | 4.9 | | | 0.9
White only, not Hispanic | | 5.9 | | | 0.3
Below 100% | | 9.6 | | | 1.1
100%–199% | | 10.6 | | | 0.8
200%–399% | | 6.4 | | | 0.6
400% or more | | 1.9 | | | 0.3
Black or African American only, not Hispanic | | 6.5 | | | 0.5
Below 100% | | 6.4 | | | 0.8
100%–199% | | 8.5 | | | 0.9
200%–399% | | 6.2 | | | 0.8
400% or more | | *3.1 | | | 0.8
Asian only | | 8.0 | | | 0.8
Below 100% | | 14.9 | | | 2.7
100%–199% | | 14.9 | | | 2.4
200%–399% | | 8.5 | | | 1.5
400% or more | | * | | | *

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error (RSE) of 20%–30%. Data not shown have an RSE of greater than 30%.

NOTES: SE is standard error. Data are for the civilian noninstitutionalized population. Uninsured children are not covered by private insurance, Medicaid, Children’s Health Insurance Program, state-sponsored or other government-sponsored health plans, Medicare, or military plans. Children with Indian Health Service only are considered to have no coverage. Health insurance coverage is at the time of interview. Persons of Hispanic origin may be of any race. Asian race includes persons of both Hispanic and non-Hispanic origin. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Missing family income data were imputed for 2000 and beyond. See Appendix II, Health insurance coverage; Family income; Hispanic origin; Poverty; Race; Table VI. Also see Table 141.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Data table for Figure 30 Dental visits in the past year among children 2–17 years of age, by percent of poverty level and race and Hispanic origin: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig30

Characteristic | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 2008 | 2009 | 2010
Percent of poverty level | Percent
2–17 years | 74.1 | 73.3 | 74.2 | 75.0 | 76.4 | 76.2 | 75.7 | 76.7 | 77.3 | 78.4 | 78.9
Below 100% | 62.4 | 61.3 | 64.4 | 65.8 | 65.5 | 66.2 | 67.5 | 67.3 | 70.1 | 71.7 | 73.2
100%–199% | 66.1 | 64.1 | 66.9 | 66.6 | 69.0 | 68.6 | 68.4 | 70.2 | 70.1 | 75.2 | 73.4
200%–399% | 75.5 | 75.0 | 75.4 | 76.5 | 78.9 | 77.8 | 77.8 | 78.1 | 78.1 | 77.1 | 79.0
400% or more | 85.9 | 84.9 | 84.5 | 85.5 | 86.1 | 86.6 | 85.6 | 86.6 | 86.9 | 87.8 | 88.0
| SE
2–17 years | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.6 | 0.6 | 0.6 | 0.6 | 0.5
Below 100% | 1.4 | 1.4 | 1.5 | 1.4 | 1.4 | 1.4 | 1.5 | 1.7 | 1.7 | 1.6 | 1.2
100%–199% | 1.2 | 1.2 | 1.2 | 1.3 | 1.1 | 1.2 | 1.5 | 1.4 | 1.4 | 1.2 | 1.1
200%–399% | 0.8 | 0.9 | 0.9 | 1.0 | 0.8 | 0.9 | 1.1 | 1.0 | 1.1 | 1.2 | 1.0
400% or more | 0.7 | 0.7 | 0.8 | 0.8 | 0.8 | 0.7 | 0.9 | 0.8 | 0.9 | 0.9 | 0.8
Race and Hispanic origin and percent of poverty level, 2009–2010 | Percent | | | SE
Hispanic | | 73.9 | | | 0.8
Below 100% | | 73.0 | | | 1.5
100%–199% | | 71.7 | | | 1.4
200%–399% | | 75.1 | | | 1.5
400% or more | | 80.5 | | | 2.1
White only, not Hispanic | | 81.2 | | | 0.6
Below 100% | | 69.3 | | | 2.1
100%–199% | | 75.7 | | | 1.3
200%–399% | | 79.3 | | | 1.0
400% or more | | 89.2 | | | 0.7
Black or African American only, not Hispanic | | 78.0 | | | 1.0
Below 100% | | 76.0 | | | 1.7
100%–199% | | 77.5 | | | 1.8
200%–399% | | 77.8 | | | 2.1
400% or more | | 86.0 | | | 1.9
Asian only | | 75.5 | | | 1.7
Below 100% | | 66.1 | | | 4.5
100%–199% | | 63.7 | | | 3.9
200%–399% | | 77.6 | | | 3.1
400% or more | | 83.5 | | | 2.3

NOTES: SE is standard error. Data are for the civilian noninstitutionalized population. Respondents were asked “About how long has it been since you last saw or talked to a dentist?” Persons of Hispanic origin may be of any race. Asian race includes persons of both Hispanic and non-Hispanic origin. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Missing family income data were imputed for 2000 and beyond. See Appendix II, Dental visit; Family income; Hispanic origin; Poverty; Race; Table VI. Also see Table 98.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

## Adults

Data table for Figure 31 Adults 18 years of age and over, by percent of poverty level and race and Hispanic origin: United States, 1990–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig31

| | Race and Hispanic origin
Characteristic | All adults | Hispanic | White, not Hispanic | Black | Asian
Year | Percent below poverty
1990 | 11.0 | 22.5 | 7.7 | 25.6 | 9.9
1991 | 11.5 | 22.5 | 8.2 | 26.2 | 12.4
1992 | 12.1 | 23.9 | 8.5 | 26.7 | 11.2
1993 | 12.4 | 24.9 | 8.7 | 26.4 | 14.1
1994 | 11.9 | 24.6 | 8.4 | 23.9 | 13.3
1995 | 11.3 | 24.8 | 7.7 | 22.9 | 12.5
1996 | 11.3 | 23.3 | 7.8 | 22.7 | 12.4
1997 | 10.9 | 21.9 | 7.7 | 21.2 | 11.4
1998 | 10.5 | 20.8 | 7.4 | 21.0 | 10.3
1999 | 10.0 | 18.6 | 7.1 | 19.1 | 10.3
2000 | 9.6 | 17.9 | 6.9 | 18.4 | 8.9
2001 | 10.1 | 18.0 | 7.4 | 19.1 | 9.8
2002 | 10.6 | 18.4 | 7.6 | 20.3 | 9.6
2003 | 10.7 | 18.7 | 7.7 | 19.9 | 11.6
2004 | 11.0 | 18.3 | 8.1 | 20.8 | 9.8
2005 | 10.9 | 18.4 | 7.8 | 20.8 | 11.2
2006 | 10.6 | 17.4 | 7.7 | 20.3 | 9.7
2007 | 10.8 | 17.9 | 7.6 | 20.2 | 9.5
2008 | 11.3 | 19.3 | 8.1 | 20.5 | 11.0
2009 | 12.3 | 21.2 | 8.8 | 21.7 | 12.0
2010 | 12.9 | 22.0 | 9.3 | 22.7 | 11.4
Percent of poverty level, 2010 | Percent distribution
Total | 100.0% | 100.0% | 100.0% | 100.0% | 100.0%
Below 100% | 12.9 | 22.0 | 9.3 | 22.7 | 11.4
100%–199% | 17.9 | 27.0 | 15.2 | 23.1 | 15.5
200%–399% | 30.5 | 32.0 | 30.4 | 30.6 | 28.0
400% or more | 38.7 | 19.0 | 45.1 | 23.6 | 45.1

NOTES: Persons of Hispanic origin may be of any race. Prior to 2002, estimates included persons who reported more than one race. Starting in 2002, estimates are for persons who reported a single race. Also starting in 2002, the category Asian and Pacific Islander was changed to Asian. Percent distribution may not total to 100% because of rounding.

SOURCE: U.S. Census Bureau, Current Population Survey, Annual Social and Economic (ASEC) Supplement: http://www.census.gov/hhes/www/cpstables/032011/pov/new01_000.htm and http://www.census.gov/hhes/www/poverty/data/historical/people.html.

Data table for Figure 32 Life expectancy at age 25, by sex and education level: United States, 1996 and 2006

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig32

| Years of expected life remaining at age 25
| 1996 | | | | 2006
| Men | | Women | | Men | | Women
Education level | Years | SE | Years | SE | Years | SE | Years | SE
No high school diploma | 47.0 | 0.3 | 53.0 | 0.3 | 47.1 | 0.4 | 51.7 | 0.5
High school graduate or GED | 50.4 | 0.2 | 56.6 | 0.2 | 51.4 | 0.3 | 57.0 | 0.3
Some college | 51.3 | 0.3 | 58.0 | 0.3 | 52.3 | 0.4 | 58.1 | 0.3
Bachelor’s degree or higher | 54.4 | 0.3 | 58.8 | 0.4 | 56.4 | 0.3 | 60.3 | 0.4

NOTES: SE is standard error; GED is General Educational Development high school equivalency diploma. Data are for the civilian noninstitutionalized population. NHIS years 1990–1994 were pooled with mortality follow-up through December 31, 1996. NHIS years 2000–2004 were pooled with mortality follow-up through December 31, 2006. Education is based on respondent-reported data in the National Health Interview Survey (NHIS). This sample is restricted to NHIS adults 25 years and older who were eligible for mortality follow-up and not missing information on education or marital status. Life expectancy was estimated using a person-year approach to calculate standard life-table functions (U.S. Bureau of the Census, 1971; Chiang, 1984). For more information see: The National Health Interview Survey (1986–2004) Linked Mortality Files, mortality follow-up through 2006: Matching Methodology, May 2009. Hyattsville, Maryland. Available from: http://www.cdc.gov/nchs/data/datalinkage/matching_methodology_nhis_final.pdf.

SOURCE: CDC/NCHS, National Health Interview Survey Linked Mortality File. See Appendix I, National Health Interview Survey (NHIS) Linked Mortality File.

Data table for Figure 33 Depression among adults 20 years of age and over, by age and percent of poverty level: United States, 2005–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig33

| 2005–2010
Age and percent of poverty level | Percent | SE
20 years and over | 7.2 | 0.4
Below 100% | 16.8 | 0.9
100%–199% | 10.3 | 0.7
200%–399% | 5.2 | 0.4
400% or more | 3.7 | 0.4
20–44 years | 7.0 | 0.4
Below 100% | 15.2 | 1.0
100%–199% | 9.6 | 1.0
200%–399% | 4.9 | 0.6
400% or more | 3.1 | 0.5
45–64 years | 8.8 | 0.6
Below 100% | 23.5 | 1.8
100%–199% | 14.8 | 1.4
200%–399% | 7.4 | 1.1
400% or more | 4.6 | 0.6
65 years and over | 4.4 | 0.4
Below 100% | 10.6 | 1.9
100%–199% | 6.8 | 0.9
200%–399% | 2.7 | 0.5
400% or more | *2.1 | 0.6

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error (RSE) of 20%–30%.

NOTES: SE is standard error. Data are for the civilian noninstitutionalized population. Totals include those with unknown poverty level. The nine-item Patient Health Questionnaire was used to identify persons with depression. Respondents were asked a series of questions about the frequency of symptoms of depression over the past 2 weeks. Response categories were given a score and summed across questions, yielding a total score ranging from 0 to 27. Respondents with a total score of 10 or higher were classified as having depression. For more information, see: Pratt LA, Brody DJ. Depression in the United States household population, 2005–2006. NCHS data brief no 7, Hyattsville, MD: NCHS. 2008. See Appendix II, Family income; Poverty.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey. See Appendix I, National Health and Nutrition Examination Survey (NHANES).

Data table for Figure 34 Edentulism (lack of natural teeth) among adults 45 years of age and over, by age and percent of poverty level: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig34

Age and percent of poverty level | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 2008 | 2009 | 2010
| Percent
45 years and over | 16.9 | 15.7 | 15.1 | 13.6 | 14.2 | 13.4 | 13.8 | 13.4 | 14.0 | 12.7 | 12.8
Below 100% | 30.2 | 27.6 | 29.9 | 25.0 | 26.5 | 25.9 | 22.6 | 23.6 | 26.3 | 24.7 | 23.1
100%–199% | 29.8 | 27.3 | 25.6 | 22.9 | 24.0 | 23.7 | 23.3 | 23.6 | 25.5 | 23.7 | 22.6
200%–399% | 17.4 | 16.3 | 16.2 | 14.6 | 15.6 | 14.3 | 15.8 | 15.0 | 15.4 | 13.9 | 14.2
400% or more | 7.9 | 7.6 | 6.6 | 6.4 | 6.4 | 5.6 | 5.9 | 6.3 | 6.2 | 4.9 | 5.3
45–64 years | 10.2 | 9.3 | 8.5 | 7.7 | 8.5 | 7.0 | 8.0 | 7.4 | 8.5 | 7.3 | 7.3
Below 100% | 19.4 | 17.9 | 20.2 | 17.0 | 19.0 | 15.8 | 14.7 | 14.6 | 19.5 | 17.0 | 14.9
100%–199% | 19.3 | 16.0 | 13.9 | 13.7 | 15.0 | 12.3 | 14.8 | 13.5 | 15.1 | 13.4 | 14.5
200%–399% | 11.8 | 10.0 | 10.0 | 8.8 | 9.1 | 7.6 | 9.4 | 7.9 | 9.5 | 7.9 | 8.1
400% or more | 5.5 | 5.9 | 4.5 | 3.9 | 4.7 | 3.7 | 3.8 | 4.4 | 4.3 | 3.3 | 3.0
65 years and over | 29.4 | 27.7 | 28.0 | 25.4 | 25.7 | 26.6 | 25.9 | 26.0 | 25.6 | 24.1 | 24.3
Below 100% | 45.2 | 43.1 | 44.1 | 38.4 | 38.3 | 43.0 | 37.2 | 39.6 | 40.9 | 41.4 | 40.6
100%–199% | 38.9 | 37.4 | 36.3 | 32.0 | 33.0 | 36.1 | 32.9 | 35.2 | 36.7 | 36.3 | 32.7
200%–399% | 24.8 | 25.2 | 24.9 | 23.0 | 25.4 | 24.9 | 26.4 | 26.4 | 24.4 | 23.5 | 23.4
400% or more | 18.0 | 14.4 | 15.5 | 16.5 | 13.1 | 13.0 | 13.8 | 13.2 | 13.1 | 10.2 | 13.1
| SE
45 years and over | 0.4 | 0.3 | 0.3 | 0.4 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4 | 0.4 | 0.3
Below 100% | 1.3 | 1.2 | 1.3 | 1.2 | 1.2 | 1.3 | 1.4 | 1.4 | 1.5 | 1.4 | 1.2
100%–199% | 1.0 | 1.0 | 1.0 | 0.9 | 0.9 | 0.9 | 1.1 | 1.1 | 1.2 | 1.0 | 0.9
200%–399% | 0.7 | 0.6 | 0.6 | 0.6 | 0.6 | 0.6 | 0.8 | 0.8 | 0.7 | 0.7 | 0.6
400% or more | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.6 | 0.4 | 0.3 | 0.4
45–64 years | 0.4 | 0.4 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4 | 0.3 | 0.3
Below 100% | 1.6 | 1.5 | 1.5 | 1.3 | 1.5 | 1.4 | 1.4 | 1.5 | 1.8 | 1.5 | 1.2
100%–199% | 1.4 | 1.3 | 1.3 | 1.1 | 1.3 | 1.2 | 1.4 | 1.3 | 1.4 | 1.2 | 1.1
200%–399% | 0.8 | 0.7 | 0.7 | 0.7 | 0.7 | 0.6 | 0.9 | 0.7 | 0.8 | 0.6 | 0.6
400% or more | 0.4 | 0.4 | 0.3 | 0.3 | 0.4 | 0.3 | 0.4 | 0.6 | 0.4 | 0.3 | 0.3
65 years and over | 0.7 | 0.7 | 0.7 | 0.7 | 0.7 | 0.7 | 0.8 | 0.8 | 0.8 | 0.7 | 0.7
Below 100% | 2.0 | 2.0 | 2.1 | 2.3 | 2.1 | 2.2 | 2.5 | 2.6 | 2.7 | 2.5 | 2.3
100%–199% | 1.5 | 1.4 | 1.4 | 1.4 | 1.3 | 1.3 | 1.7 | 1.8 | 1.7 | 1.6 | 1.4
200%–399% | 1.1 | 1.1 | 1.2 | 1.2 | 1.1 | 1.1 | 1.5 | 1.6 | 1.4 | 1.3 | 1.2
400% or more | 1.4 | 1.2 | 1.5 | 1.4 | 1.1 | 1.1 | 1.5 | 1.2 | 1.2 | 1.0 | 1.2

NOTES: SE is standard error. Data are for the civilian noninstitutionalized population. Edentulism is having no natural teeth. Respondents were asked, “Have you lost all of your upper and lower natural (permanent) teeth?” Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Missing family income data were imputed for 2000 and beyond. See Appendix II, Family income; Poverty; Table VI.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Data table for Figure 35 Two or more selected chronic health conditions among adults 45–64 years of age, by percent of poverty level: United States, 1999–2000 and 2009–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig35

| 1999–2000 | | 2009–2010
Percent of poverty level | Percent | SE | Percent | SE
45–64 years | 16.1 | 0.3 | 21.0 | 0.4
Below 100% | 30.6 | 1.3 | 33.4 | 1.3
100%–199% | 23.8 | 1.1 | 29.8 | 1.1
200%–399% | 16.9 | 0.6 | 21.2 | 0.7
400% or more | 11.5 | 0.4 | 15.7 | 0.5

NOTES: SE is standard error. Data are for the civilian noninstitutionalized population. The nine possible selected chronic conditions were based on respondent’s report to the following questions: “Have you ever been told by a doctor or other health professional that you had: “...hypertension, also called high blood pressure? Were you told on two or more different visits that you had hypertension, also called high blood pressure?”; “...coronary heart disease?”; “...angina, also called angina pectoris?”; “...a heart attack (also called myocardial infarction)?”; “...any kind of heart condition or heart disease (other than the ones that I just asked about?)”; “...a stroke?”; “...emphysema?”; “...other than during pregnancy, diabetes or sugar diabetes?”; “...cancer or a malignancy of any kind?”; “What kind of cancer was it?”. Respondents were also asked the following questions about the past year: “During the past 12 months, have you had an episode of asthma or an asthma attack?”; “During the past 12 months, have you been told by a doctor or other health professional that you had chronic bronchitis?”; “...weak or failing kidneys? Do not include kidney stones, bladder infections, or incontinence.” The four types of heart disease questions were combined into one variable to indicate heart disease. For hypertension, respondents had to have been told on two or more different visits. Persons who responded borderline diabetes were recoded to no for diabetes. Persons who responded yes to only nonmelanoma skin cancer were recoded to no for cancer. Adults had to be known on two or more of the selected nine conditions to be included in the analysis. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Missing family income data were imputed for 1999–2000 and 2009–2010. See Appendix II, Family income; Poverty; Table VI.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Data table for Figure 36 Basic actions difficulty or complex activity limitation among adults 18 years of age and over, by age and percent of poverty level: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig36

Age and percent of poverty level | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 2008 | 2009 | 2010
| Percent
18 years and over | 29.5 | 32.7 | 30.7 | 31.2 | 30.9 | 31.2 | 31.7 | 31.5 | 32.5 | 32.0 | 32.8
Below 100% | 42.3 | 43.7 | 41.7 | 42.0 | 43.8 | 43.4 | 43.2 | 43.6 | 46.5 | 42.7 | 43.9
100%–199% | 39.9 | 43.4 | 39.9 | 41.5 | 40.1 | 40.8 | 40.8 | 40.7 | 43.6 | 41.0 | 41.6
200%–399% | 29.9 | 33.6 | 31.8 | 31.7 | 31.0 | 31.7 | 31.5 | 31.3 | 33.2 | 33.4 | 33.1
400% or more | 20.8 | 23.9 | 22.4 | 22.5 | 22.6 | 22.6 | 23.3 | 23.8 | 22.7 | 23.0 | 24.1
18–64 years | 23.5 | 26.6 | 24.8 | 25.3 | 24.9 | 25.3 | 25.6 | 25.8 | 26.8 | 26.4 | 27.1
Below 100%. | 35.8 | 37.8 | 35.9 | 36.3 | 38.3 | 38.1 | 38.0 | 38.1 | 42.4 | 38.1 | 39.7
100%–199% | 29.1 | 33.6 | 30.4 | 32.1 | 31.0 | 32.0 | 31.8 | 32.2 | 34.8 | 33.5 | 33.4
200%–399%. | 23.7 | 26.7 | 25.1 | 24.8 | 23.9 | 24.8 | 24.2 | 24.5 | 25.9 | 26.2 | 25.9
400% or more | 18.0 | 20.8 | 19.3 | 19.5 | 19.2 | 19.2 | 19.7 | 20.2 | 19.5 | 19.6 | 20.4
65 years and over | 60.8 | 64.6 | 61.8 | 62.4 | 62.8 | 62.4 | 63.8 | 62.0 | 62.2 | 60.8 | 61.7
Below 100%. | 74.9 | 78.5 | 72.9 | 76.3 | 74.7 | 76.0 | 78.2 | 79.9 | 77.1 | 76.2 | 75.4
100%–199% | 72.4 | 72.6 | 69.1 | 72.0 | 71.3 | 71.0 | 71.0 | 71.4 | 73.8 | 69.4 | 72.2
200%–399%. | 56.2 | 63.5 | 60.1 | 60.7 | 61.1 | 61.4 | 64.0 | 61.3 | 64.0 | 63.9 | 61.5
400% or more | 47.4 | 51.8 | 50.5 | 48.7 | 51.4 | 49.7 | 50.8 | 49.2 | 46.2 | 46.0 | 48.8
| SE
18 years and over | 0.3 | 0.4 | 0.4 | 0.4 | 0.3 | 0.4 | 0.4 | 0.4 | 0.5 | 0.4 | 0.4
Below 100%. | 1.1 | 1.1 | 1.2 | 1.1 | 1.1 | 1.1 | 1.2 | 1.4 | 1.3 | 1.2 | 1.0
100%–199% | 0.8 | 0.8 | 0.8 | 0.8 | 0.8 | 0.9 | 0.9 | 1.0 | 1.1 | 1.0 | 0.9
200%–399%. | 0.6 | 0.6 | 0.6 | 0.6 | 0.6 | 0.7 | 0.7 | 0.7 | 0.8 | 0.7 | 0.7
400% or more | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.6 | 0.6 | 0.6 | 0.6 | 0.6
18–64 years | 0.3 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.4 | 0.5 | 0.4 | 0.4
Below 100%. | 1.1 | 1.1 | 1.2 | 1.1 | 1.1 | 1.2 | 1.3 | 1.5 | 1.4 | 1.2 | 1.1
100%–199% | 0.9 | 1.0 | 0.9 | 0.9 | 0.9 | 1.0 | 1.0 | 1.1 | 1.1 | 1.1 | 1.0
200%–399%. | 0.6 | 0.6 | 0.6 | 0.7 | 0.6 | 0.8 | 0.7 | 0.8 | 0.8 | 0.8 | 0.7
400% or more | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.5 | 0.6 | 0.6 | 0.7 | 0.6 | 0.6
65 years and over | 0.8 | 0.8 | 0.8 | 0.8 | 0.8 | 0.7 | 0.9 | 0.9 | 0.9 | 0.9 | 0.8
Below 100%. | 2.0 | 1.9 | 2.1 | 1.9 | 2.0 | 2.1 | 2.4 | 2.4 | 2.6 | 2.3 | 2.3
100%–199% | 1.2 | 1.3 | 1.3 | 1.4 | 1.3 | 1.6 | 1.6 | 1.9 | 1.7 | 1.7 | 1.5
200%–399%. | 1.3 | 1.4 | 1.3 | 1.4 | 1.3 | 1.5 | 1.6 | 1.8 | 1.5 | 1.5 | 1.4
400% or more | 1.8 | 1.8 | 1.8 | 2.0 | 1.7 | 1.7 | 1.9 | 1.9 | 1.8 | 1.8 | 1.6

NOTES: SE is standard error. Data are for the civilian noninstitutionalized population. Any basic actions difficulty or complex activity limitation is defined as having one or more of the following limitations or difficulties: movement difficulty, emotional difficulty, sensory (seeing or hearing) difficulty, cognitive difficulty, self-care (activities of daily living or instrumental activities of daily living) limitation, social limitation, or work limitation. Starting with 2007 data, the hearing question, a component of the basic actions difficulty measure, was revised. Consequently, data prior to 2007 are not comparable with data for 2007 and beyond. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Missing family income data were imputed for 2000 and beyond. See Appendix II, Basic actions difficulty; Complex activity limitation; Family income; Hearing trouble; Poverty; Table VI. Also see Table 54.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Data table for Figure 37 Obesity among adults 25 years of age and over, by sex and education level: United States, 1988–1994 and 2007–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig37

| 1988–1994 | | 2007–2010
Sex and education level | Percent | SE | Percent | SE
Adults, 25 years and over | 23.5 | 0.7 | 36.0 | 0.7
No high school diploma | 27.7 | 1.0 | 38.6 | 1.3
High school graduate or GED | 25.5 | 1.1 | 37.9 | 1.5
Some college | 23.3 | 1.3 | 41.4 | 0.8
Bachelor’s degree or higher | 15.8 | 1.3 | 26.9 | 1.4
Men, 25 years and over. | 20.6 | 0.8 | 35.4 | 1.1
No high school diploma | 23.0 | 1.3 | 33.8 | 2.2
High school graduate or GED | 21.9 | 1.5 | 36.5 | 2.3
Some college | 21.2 | 2.0 | 42.6 | 1.3
Bachelor’s degree or higher | 16.1 | 1.7 | 28.4 | 2.2
Women, 25 years and over | 26.3 | 1.0 | 36.5 | 0.8
No high school diploma | 32.2 | 1.5 | 43.1 | 1.6
High school graduate or GED | 28.3 | 1.5 | 39.2 | 1.4
Some college | 25.2 | 1.6 | 40.4 | 1.1
Bachelor’s degree or higher | 15.5 | 1.5 | 25.3 | 1.5
Age-adjusted
Adults, 25 years and over | 23.9 | 0.7 | 35.7 | 0.7
No high school diploma | 28.0 | 1.1 | 38.5 | 1.3
High school graduate or GED | 25.8 | 1.1 | 37.6 | 1.4
Some college | 23.1 | 1.2 | 41.1 | 0.9
Bachelor’s degree or higher | 16.5 | 1.5 | 26.8 | 1.4
Men, 25 years and over. | 21.0 | 0.8 | 35.2 | 1.1
No high school diploma | 23.1 | 1.3 | 33.4 | 2.2
High school graduate or GED | 22.4 | 1.5 | 36.5 | 2.2
Some college | 21.7 | 2.2 | 42.4 | 1.3
Bachelor’s degree or higher | 16.4 | 1.7 | 28.4 | 2.3
Women, 25 years and over | 26.7 | 1.0 | 36.2 | 0.7
No high school diploma | 32.9 | 1.8 | 43.6 | 1.7
High school graduate or GED | 28.4 | 1.5 | 39.0 | 1.4
Some college | 24.7 | 1.5 | 40.1 | 1.1
Bachelor’s degree or higher | 17.0 | 1.7 | 25.5 | 1.5

NOTES: SE is standard error. GED is General Educational Development high school equivalency diploma. Data are for the civilian noninstitutionalized population. Totals include those with unknown education level. Obesity is defined as a body mass index (BMI) equal to or greater than 30. Pregnant women were excluded. Age-adjusted estimates are adjusted using three age groups: 25–44 years, 45–64 years, and 65 years and over. See Appendix II, Age adjustment; Body mass index (BMI); Education. Also see Table 74.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey. See Appendix I, National Health and Nutrition Examination Survey (NHANES).

Data table for Figure 38 Current cigarette smoking among adults 25 years of age and over, by age and education level: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig38

Age and education level | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 2008 | 2009 | 2010
| Percent
25 years and over | 22.7 | 22.1 | 21.5 | 21.2 | 20.5 | 20.4 | 20.4 | 19.4 | 20.5 | 20.4 | 19.2
25–64 years | 25.7 | 24.9 | 24.3 | 24.0 | 23.1 | 23.1 | 22.7 | 21.9 | 23.2 | 23.0 | 21.6
No high school diploma | 36.0 | 34.9 | 34.8 | 34.0 | 33.6 | 32.3 | 32.6 | 30.9 | 33.8 | 33.1 | 30.8
High school graduate or GED | 33.9 | 32.0 | 32.3 | 31.8 | 29.4 | 31.1 | 29.8 | 30.1 | 32.4 | 32.2 | 31.2
Some college | 24.6 | 25.3 | 24.6 | 24.1 | 24.5 | 24.7 | 24.9 | 23.0 | 25.0 | 24.3 | 23.5
Bachelor’s degree or higher | 12.3 | 12.1 | 10.9 | 11.1 | 10.9 | 10.0 | 9.1 | 10.4 | 9.5 | 9.7 | 9.1
65 years and over | 9.7 | 10.1 | 9.3 | 9.1 | 8.8 | 8.6 | 10.2 | 8.3 | 9.3 | 9.5 | 9.5
No high school diploma | 12.0 | 12.0 | 12.0 | 10.4 | 9.7 | 10.4 | 13.1 | 9.7 | 13.2 | 10.5 | 12.0
High school graduate or GED | 9.4 | 10.9 | 8.9 | 9.7 | 9.5 | 8.5 | 11.2 | 10.2 | 8.4 | 11.5 | 9.2
Some college | 10.0 | 9.6 | 8.6 | 8.3 | 8.2 | 9.5 | 10.4 | 8.0 | 10.3 | 9.2 | 11.0
Bachelor’s degree or higher | 4.8 | 5.5 | 6.3 | 6.7 | 6.5 | 5.4 | 4.6 | 4.0 | 4.8 | 6.0 | 5.4
| SE
25 years and over | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.4 | 0.4 | 0.4 | 0.4 | 0.3
25–64 years | 0.4 | 0.4 | 0.4 | 0.3 | 0.4 | 0.3 | 0.4 | 0.5 | 0.5 | 0.4 | 0.4
No high school diploma | 0.9 | 0.9 | 1.0 | 1.0 | 1.0 | 1.0 | 1.1 | 1.2 | 1.3 | 1.3 | 1.1
High school graduate or GED | 0.7 | 0.7 | 0.7 | 0.7 | 0.7 | 0.7 | 0.9 | 1.0 | 0.9 | 0.8 | 0.9
Some college | 0.6 | 0.6 | 0.6 | 0.6 | 0.6 | 0.6 | 0.8 | 0.8 | 0.8 | 0.7 | 0.7
Bachelor’s degree or higher | 0.5 | 0.4 | 0.5 | 0.5 | 0.5 | 0.4 | 0.5 | 0.6 | 0.5 | 0.5 | 0.4
65 years and over | 0.4 | 0.6 | 0.4 | 0.4 | 0.4 | 0.4 | 0.5 | 0.5 | 0.5 | 0.5 | 0.5
No high school diploma | 0.8 | 0.8 | 0.8 | 0.9 | 0.8 | 0.8 | 1.1 | 1.0 | 1.2 | 1.0 | 1.1
High school graduate or GED | 0.7 | 0.8 | 0.7 | 0.7 | 0.8 | 0.7 | 1.0 | 1.0 | 0.8 | 1.0 | 0.8
Some college | 1.0 | 0.9 | 0.9 | 0.8 | 0.9 | 1.0 | 1.2 | 1.0 | 1.2 | 0.9 | 1.1
Bachelor’s degree or higher | 0.8 | 0.8 | 0.9 | 0.9 | 0.8 | 0.8 | 0.8 | 0.8 | 0.9 | 0.9 | 0.8

NOTES: SE is standard error. GED is General Educational Development high school equivalency diploma. Data are for the civilian noninstitutionalized population. Totals include those with unknown education level. Current cigarette smoking is defined as ever smoked 100 cigarettes in their lifetime and now smoke every day or some days. See Appendix II, Cigarette smoking; Education. Also see Tables 60–62.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Data table for Figure 39 Colorectal tests or procedures among adults 50–75 years of age, by education level: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig39

| 2000 | | 2003 | | 2005 | | 2008 | | 2010
Education level | Percent | SE | Percent | SE | Percent | SE | Percent | SE | Percent | SE
50–75 years | 33.9 | 0.6 | 39.1 | 0.6 | 44.3 | 0.6 | 51.6 | 0.7 | 58.7 | 0.7
No high school diploma | 25.9 | 1.1 | 28.9 | 1.2 | 34.5 | 1.4 | 36.2 | 1.7 | 44.6 | 1.5
High school graduate or GED | 33.1 | 1.0 | 38.3 | 1.1 | 42.1 | 1.1 | 48.5 | 1.3 | 53.7 | 1.2
Some college | 36.4 | 1.1 | 40.2 | 1.2 | 44.8 | 1.2 | 54.5 | 1.3 | 62.0 | 1.1
Bachelor’s degree or higher | 39.2 | 1.3 | 46.5 | 1.2 | 52.4 | 1.2 | 60.6 | 1.3 | 67.3 | 1.1

NOTES: SE is standard error. GED is General Educational Development high school equivalency diploma. Data are for the civilian noninstitutionalized population. Totals include those with unknown education level. Colorectal tests or procedures include reports of home fecal occult blood test (FOBT) in the past year, sigmoidoscopy procedure in the past 5 years with FOBT in the past 3 years, or colonoscopy in the past 10 years. Colorectal tests or procedures are performed for diagnostic and screening purposes. See Appendix II, Colorectal tests or procedures; Education. Also see Table 92.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Data table for Figure 40 No health insurance coverage among adults 18–64 years of age, by percent of poverty level and race and Hispanic origin: United States, 2000–2011

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig40

Characteristic | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 2008 | 2009 | 2010
Percent of poverty level | Percent
18–64 years | 18.9 | 18.5 | 19.3 | 19.3 | 19.3 | 19.3 | 20.0 | 19.6 | 19.9 | 21.2 | 22.3
Below 100% | 42.4 | 41.3 | 38.9 | 39.9 | 41.0 | 40.9 | 40.7 | 38.6 | 38.6 | 42.5 | 42.7
100%–199% | 36.4 | 35.0 | 35.5 | 37.5 | 36.5 | 35.9 | 36.7 | 37.9 | 38.9 | 38.9 | 42.1
200%–399%. | 18.2 | 17.8 | 19.7 | 18.8 | 19.1 | 19.0 | 18.8 | 20.5 | 20.2 | 21.7 | 21.3
400% or more | 6.6 | 6.9 | 7.4 | 6.4 | 6.8 | 7.1 | 7.4 | 6.5 | 7.1 | 6.7 | 6.5
| SE
18–64 years | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3 | 0.3
Below 100% | 0.9 | 0.9 | 1.0 | 1.0 | 0.9 | 0.9 | 1.1 | 1.3 | 1.2 | 1.0 | 0.9
100%–199% | 0.7 | 0.7 | 0.7 | 0.8 | 0.8 | 0.7 | 0.8 | 0.8 | 0.8 | 0.8 | 0.8
200%–399%. | 0.5 | 0.4 | 0.5 | 0.5 | 0.5 | 0.5 | 0.6 | 0.5 | 0.5 | 0.5 | 0.5
400% or more | 0.2 | 0.2 | 0.3 | 0.2 | 0.2 | 0.2 | 0.4 | 0.3 | 0.3 | 0.3 | 0.2
Race and Hispanic origin and percent of poverty level, 2009–2010 | Percent | | SE
Hispanic | 43.3 | | 0.7
Below 100% | 61.1 | | 1.1
100%–199% | 56.5 | | 0.9
200%–399%. | 34.8 | | 0.9
400% or more | 13.6 | | 0.8
White only, not Hispanic | 16.0 | | 0.3
Below 100% | 35.0 | | 1.0
100%–199% | 33.8 | | 0.7
200%–399%. | 18.3 | | 0.4
400% or more | 5.7 | | 0.2
Black or African American only, not Hispanic | 25.7 | | 0.5
Below 100% | 36.7 | | 1.1
100%–199% | 36.7 | | 1.0
200%–399%. | 21.8 | | 0.8
400% or more | 9.5 | | 0.6
Asian only | 19.6 | | 0.8
Below 100% | 38.7 | | 2.7
100%–199% | 38.7 | | 2.3
200%–399%. | 21.8 | | 1.5
400% or more | 7.0 | | 0.7

NOTES: SE is standard error. Data are for the civilian noninstitutionalized population. Uninsured adults are not covered by private insurance, Medicaid, Children’s Health Insurance Program, state-sponsored or other government-sponsored health plans, Medicare, or military plans. Adults with Indian Health Service only are considered to have no coverage. Health insurance coverage is at the time of interview. Persons of Hispanic origin may be of any race. Asian race includes persons of both Hispanic and non-Hispanic origin. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Missing family income data were imputed for 2000 and beyond. See Appendix II, Health insurance coverage; Family income; Hispanic origin; Poverty; Race; Table VI. Also see Table 141.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Data table for Figure 41 Delay or nonreceipt of needed medical care in the past 12 months due to cost among adults 18–64 years of age, by percent of poverty level and race and Hispanic origin: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig41

Characteristic | 2000 | 2001 | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 2008 | 2009 | 2010
Percent of poverty level | Percent
18–64 years | 9.2 | 9.5 | 9.7 | 10.6 | 11.4 | 11.0 | 11.7 | 11.8 | 13.6 | 15.1 | 14.7
Below 100%. | 18.4 | 17.6 | 16.9 | 18.5 | 20.4 | 20.0 | 20.8 | 20.8 | 21.9 | 24.8 | 23.4
100%–199% | 15.8 | 16.8 | 17.2 | 18.5 | 19.3 | 18.9 | 19.1 | 19.9 | 22.5 | 24.0 | 24.0
200%–399%. | 9.6 | 10.2 | 10.4 | 10.9 | 12.1 | 11.8 | 12.0 | 13.0 | 15.0 | 16.8 | 15.2
400% or more | 4.0 | 4.0 | 4.4 | 5.1 | 5.2 | 5.0 | 5.4 | 5.3 | 6.7 | 7.2 | 6.8
| SE
18–64 years | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.3 | 0.3 | 0.2
Below 100% | 0.7 | 0.6 | 0.6 | 0.6 | 0.7 | 0.7 | 0.8 | 0.8 | 0.8 | 0.8 | 0.7
100%–199% | 0.5 | 0.5 | 0.5 | 0.6 | 0.5 | 0.5 | 0.7 | 0.6 | 0.7 | 0.6 | 0.6
200%–399%. | 0.3 | 0.3 | 0.3 | 0.4 | 0.4 | 0.3 | 0.4 | 0.4 | 0.5 | 0.5 | 0.4
400% or more | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.2 | 0.3 | 0.2 | 0.3 | 0.3 | 0.2
Race and Hispanic origin and percent of poverty level, 2009–2010 | Percent | | SE
Hispanic | 15.9 | | 0.4
Below 100% | 21.0 | | 0.8
100%–199% | 18.3 | | 0.7
200%–399%. | 14.3 | | 0.6
400% or more | 8.0 | | 0.6
White only, not Hispanic | 14.6 | | 0.2
Below 100% | 26.6 | | 0.8
100%–199% | 27.7 | | 0.7
200%–399%. | 17.1 | | 0.5
400% or more | 7.0 | | 0.2
Black or African American only, not Hispanic | 17.1 | | 0.4
Below 100% | 23.8 | | 1.0
100%–199% | 22.7 | | 0.9
200%–399%. | 14.4 | | 0.6
400% or more | 8.6 | | 0.6
Asian only | 7.7 | | 0.4
Below 100% | 16.4 | | 1.7
100%–199% | 12.5 | | 1.3
200%–399%. | 8.4 | | 0.9
400% or more | 3.6 | | 0.4

NOTES: SE is standard error. Data are for the civilian noninstitutionalized population. Based on persons responding yes to the question, “During the past 12 months was there any time when person needed medical care but did not get it because person couldn’t afford it?” or “During the past 12 months have you delayed seeking medical care or has medical care been delayed because of worry about cost?” Persons of Hispanic origin may be of any race. Asian race includes persons of both Hispanic and non-Hispanic origin. Percent of poverty level is based on family income and family size and composition using U.S. Census Bureau poverty thresholds. Missing family income data were imputed for 2000 and beyond. See Appendix II, Family income; Hispanic origin; Poverty; Race; Table VI. Also see Table 79.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).