# Chartbook With Special Feature on Socioeconomic Status and Health

Chartbook: Figures 1–21

Chartbook: Figures 22–41: Special Feature on Socioeconomic Status and Health