# Utilization and Access

## Dental Visits Among Children

In 2010, the percentage of children 2–17 years of age who had a dental visit within the past year rose with relative family income, from 73% of those in families below the poverty level to 88% of those at 400% or more of the poverty level.

Dental caries (tooth decay) is one of the most common childhood diseases (1,2). The American Academy of Pediatric Dentistry recommends that each child see a dentist by his or her first birthday and have regular visits thereafter. Starting regular dental care for children at a young age makes regular dental care more likely and reduces later dental costs, especially for low-income children (3). Utilization of dental care and the prevalence of untreated dental caries vary by income and by race and ethnicity, with those in higher income groups and non-Hispanic whites having higher utilization and lower untreated dental caries prevalence (Table 76) (1–5).

During 2000–2010, the percentage of children 2–17 years of age who had a dental visit in the past year rose more for children below 200% of the poverty level than for those at 200% or more of poverty, narrowing the gap across relative family income groups. By 2010, the percentage of children with a recent visit was 17% lower for children living below 200% of the poverty level and 10% lower for children at 200%–399% of poverty, compared with those at 400% or more of the poverty level.

In 2009–2010, the percentage of children with a recent dental visit was lower for those in poverty compared with those living at 400% of poverty or more for each racial and ethnic group examined. The disparity across relative family income groups was smaller among Hispanic and non-Hispanic black children than for Asian and non-Hispanic white children.

Figure 30 Dental visits in the past year among children 2–17 years of age, by percent of poverty level and race and Hispanic origin: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig30

NOTE: See data table for Figure 30.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Figure 30 consists of a line graph and a bar chart showing dental visits in the past year among children 2 to 17 years of age, by percent of poverty level and race and Hispanic origin, for 2000 through 2010.

## References

1 U.S. General Accounting Office (GAO). Oral health: Factors contributing to low use of dental services by low-income populations. GAO/HEHS–00–149. Washington DC. GAO. 2000. Available from: http://www.gao.gov/archive/2000/he00149.pdf.
2 U.S. Department of Health and Human Services. Oral health in America: A report of the Surgeon General. Rockville, MD. U.S. Department of Health and Human Services, National Institute of Dental and Craniofacial Research, National Institutes of Health. 2000. Available from: http://www.nidcr.nih.gov/DataStatistics/SurgeonGeneral/sgr/.
3 Savage MF, Lee JY, Kotch JB, Vann WF Jr. Early preventive dental visits: Effects on subsequent utilization and costs. Pediatrics. 2004;114(4):e418-23. [pmid: 15466066].
4 Flores G, Tomany-Korman SC. Racial and ethnic disparities in medical and dental health access to care, and use of services in U.S. children. Pediatrics. 2008;121(2):e286-98. [pmid: 18195000].
5 Edelstein BL, Chinn CH. Update on disparities in oral health and access to dental care for America’s children. Acad Pediatr. 2009;9(6):415-9. [pmid: 19945076].