# Prevention

## Colorectal Tests or Procedures

Colorectal tests or procedures for adults 50–75 years of age increased with increasing education level in 2010.

Colorectal cancer is the third most common cancer in the United States and the leading cause of cancer deaths among nonsmokers (1,2). The U.S. Preventive Services Task Force recommends screening for colorectal cancer for adults 50–75 years of age using home fecal occult blood tests, sigmoidoscopy, or colonoscopy (1). Colorectal tests or procedures are also performed for diagnostic purposes. Recent declines in colorectal cancer deaths were attributed to increases in colorectal cancer testing (2).

In 2010, more than one-half of adults 50–75 years of age had a recent colorectal test or procedure (see data table for Figure 39 for definitions of colorectal tests or procedures). Those in higher education groups were more likely to have had a recent test or procedure. Compared with adults with a Bachelor’s degree or higher education, in 2010 the percentage with a recent colorectal test or procedure was 34% lower for those without a high school degree, 20% lower for those with a high school degree, and 8% lower for those with some college.

During 2000–2010, the percentage of adults 50–75 years of age with a colorectal test or procedure increased from one-third in 2000 to almost three-fifths in 2010. For each education group, the percentage with a recent colorectal test or procedure increased 62%–72% in the past decade.

Increases in colorectal cancer tests or procedures have occurred at a slower rate among the uninsured (2). Patient education and income, as well as provider and clinical systems factors, may all contribute to differences in utilization (2).

Figure 39 Colorectal tests or procedures among adults 50–75 years of age, by education level: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig39

NOTES: GED is General Educational Development high school equivalency diploma. See data table for Figure 39.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Figure 39 is a line graph showing colorectal tests or procedures among adults 50 to 75 years of age, by education level, for 2000 through 2010.

## References

1 U.S. Preventive Services Task Force. Screening for colorectal cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2008;149:627-37. Available from: http://www.uspreventiveservicestaskforce.org/uspstf08/colocancer/colors.pdf. [pmid: 18838716].
2 CDC. Vital Signs: Colorectal cancer screening among adults aged 50–75 years—United States, 2008. MMWR. 2010;59(26):808-12. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm5926a3.htm?s_cid=mm5926a3_w. [pmid: 20613704].