# Prevention

## Babies Who Were Breastfed for 3 Months or More

In 2002–2004, babies of mothers without a Bachelor’s degree were less likely to be breastfed for at least 3 months than babies whose mothers had a Bachelor’s degree or higher education.

Exclusive breastfeeding (without supplementing with formula or other foods) and longer duration of breastfeeding are associated with better health outcomes for mother and infant (1). Breastfeeding is associated with nutritional, immunologic, developmental, psychological, social, economic, and environmental benefits (1,2). Increasing rates of breastfeeding is a public health strategy to improve children’s health and reduce health care costs (3). The American Academy of Pediatrics recommends exclusive breastfeeding for the first 6 months of life (2). Breastfeeding rates differ by race and ethnicity, socioeconomic level, and other demographic factors (Table 14) (3). In 2002–2004, non-Hispanic black babies were about half as likely to be breastfed for at least 3 months than non-Hispanic white and Hispanic babies (Table 14).

In 2002–2004, babies of mothers with less than a Bachelor’s degree were about 40% less likely to be breastfed for at least 3 months than babies of mothers with a Bachelor’s degree or higher education. Throughout the period 1992–1994 to 2002–2004, breastfeeding was more likely for babies whose mothers had a Bachelor’s degree or higher than for those with less education. During this period, breastfeeding increased for mothers of all education levels, except among mothers with some college. The largest percentage increase in breastfeeding during this decade occurred among mothers without a high school diploma, resulting in a narrowing of the gap in breastfeeding rates between mothers in the lowest and highest education groups.

Figure 27 Babies breastfed 3 months or more among mothers 22–44 years of age, by mother’s education level: United States, 1992–1994 through 2002–2004

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig27

NOTES: GED is General Educational Development high school equivalency diploma. See data table for Figure 27.

SOURCE: CDC/NCHS, National Survey of Family Growth. See Appendix I, National Survey of Family Growth (NSFG).

Figure 27 is a line graph showing babies breastfed 3 months or more among mothers 22 to 44 years of age, by mother’s education level, for 1992 to 1994 through 2002 to 2004.

### References

1 U.S. Department of Health and Human Services. The Surgeon General’s call to action to support breastfeeding. Washington, DC. U.S. Department of Health and Human Services, Office of the Surgeon General. 2011. Available from: http://www.surgeongeneral.gov/initiatives/breastfeeding/.
2 American Academy of Pediatrics. Breastfeeding and the use of human milk. Pediatrics. 2005;115(2):496-506. Available from: http://pediatrics.aappublications.org/content/115/2/496.full. [pmid: 15687461].
3 CDC. Racial and Socioeconomic disparities in breastfeeding— United States, 2004. MMWR. 2006;55(12):335-9. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm5512a3.htm. [pmid: 16572102].

## Adolescent Vaccinations

In 2009, adolescents living in families below 400% of the poverty level were less likely to have been vaccinated against meningococcal disease and to have received all three doses of human papillomavirus vaccine than adolescents living in families at 400% or more of the poverty level.

Vaccination of children and teenagers against communicable diseases is an important public health strategy (1). Vaccinations are required for public school attendance, but the timing, number, and type varies by state (2). Ideally, adolescents should have completed the recommended series for measles, mumps, and rubella; hepatitis B; and varicella during early childhood.

Vaccinations recommended for the preteen to teenage years include tetanus and diphtheria toxoids and acellular pertussis vaccine (Tdap), meningococcal conjugate vaccine (MenACWY), and three doses of human papillomavirus vaccine (HPV) (1). MenACWY was recommended for use in May 2005 and HPV for females in March 2007 (3–5). Vaccinations may be expensive but are often covered by health insurance. Uninsured or underinsured children may receive vaccinations at little or no cost through CDC’s Vaccines for Children Program (6).

In 2009, adolescents living in poverty were less likely to have had recommended vaccinations compared with adolescents living in families with income at 400% or more of the poverty level. The differences in vaccination rates by relative family income were larger for HPV and MenACWY than for other vaccines. Compared with the highest relative family income group, the percentage vaccinated in the three lower groups was 8 to 12 percentage points lower for MenACWY and 7 to 10 percentage points lower for three doses of HPV. Although females living below the poverty level were more likely than those above poverty to initiate HPV vaccination, they were less likely to complete the series (7).

Figure 28 Vaccinations among adolescents 13–17 years of age, by type of vaccine and percent of poverty level: United States, 2009

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig28

NOTES: Vaccine types: MMR is measles, mumps, rubella; Hep B is hepatitis B; varicella is chickenpox; Tdap is tetanus and diphtheria toxoids and acellular pertussis; MenACWY is meningococcal conjugate; and HPV is human papillomavirus (reported for females). See data table for Figure 28.

SOURCE: CDC/NCHS and National Center for Immunization and Respiratory Diseases, National Immunization Survey– Teen. See Appendix I, National Immunization Survey (NIS).

Figure 28 consists of two bar charts showing vaccinations among adolescents 13 to 17 years of age, by type of vaccine and percent of poverty level, for 2009.

### References

1 CDC. Recommended immunization schedules for persons aged 0 through 18 years—United States, 2011. MMWR. 2011;60(5). Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm6005a6.htm?s_cid=mm6005a6_w.
2 CDC. State vaccination requirements. 2011. Available from: http://www.cdc.gov/vaccines/vac-gen/laws/state-reqs.htm.
3 CDC. Quadrivalent human papillomavirus vaccine: Recommendations of the Advisory Committee on Immunization Practices (ACIP). MMWR. 2007;56(RR–2):1-24. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/rr5602a1.htm.
4 CDC. Prevention and control of meningococcal disease: Recommendations of the Advisory Committee on Immunization Practices (ACIP). MMWR. 2005;54(RR–7):1-21. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/rr5407a1.htm.
5 CDC. Updated recommendations for use of meningococcal conjugate vaccines—Advisory Committee on Immunization Practices (ACIP), 2010. MMWR. 2011;60(03):72-6. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm6003a3.htm?s_cid=mm6003a3_e. [pmid: 21270745].
6 CDC. Vaccines for Children Program (VFC). 2011. Available from: http://www.cdc.gov/vaccines/programs/vfc/default.htm.
7 CDC. National, state, and local area vaccination coverage among adolescents aged 13–17 years—United States, 2009. MMWR. 2010;59(32):1018-23. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm5932a3.htm. [pmid: 20724968].