# Morbidity

## Depression

In 2005–2010, depression prevalence among adults 20 years of age and over living below the poverty level was more than four times as high as for those with family income at 400% or more of the poverty level.

Depression is a common condition that is associated with increased morbidity and mortality, reduced productivity, and poorer quality of life (1–6). Its symptoms include difficulties with mood, sleep, and concentration, and loss of interest or pleasure in doing things. Major depression may be incapacitating (5,6). Despite the introduction of new antidepressant drugs in recent decades, depression remains underdiagnosed and inadequately treated (1,5,7).

Depression was measured using the Patient Health Questionnaire—a screening instrument that asks a series of questions in which respondents indicated how frequently they felt down, had trouble sleeping, had little energy, and other symptoms over the past 2 weeks. Responses were scored based on the frequency of these symptoms (8); a score of 10 or higher (out of 27) was classified as depression (8,9).

In 2005–2010, among adults 20–44 and 45–64 years of age, depression was five times as high for those below poverty, about three times as high for those with family income at 100%–199% of poverty, and 60% higher for those with income at 200%–399% of poverty compared with those at 400% or more of the poverty level. For adults 65 years of age and over, depression was five times as high for those below poverty, about three times as high for those with family income at 100%–199% of poverty, and similar for those with income at 200%–399% compared with those at 400% or more of the poverty level.

Previous studies have shown an association between SES and depression, although the nature and direction of this association are not clear (2,8,10). Low SES may contribute to developing depression and may also be a result of reduced earning potential or productivity due to depression (10,11).

Figure 33 Depression among adults 20 years of age and over, by age and percent of poverty level: United States, 2005–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig33

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error of 20%–30%.

NOTE: See data table for Figure 33.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey. See Appendix I, National Health and Nutrition Examination Survey (NHANES).

Figure 33 is a bar chart showing depression prevalence among adults 20 years of age and over, by age group and percent of poverty level, for 2005 through 2010.

### References

1 Timonen M, Liukkonen T. Management of depression in adults. BMJ. 2008;336(7641):435-9. [pmid: 18292169].
2 Kessler RC, Berglund P, Demler O, Jin R, Koretz D, Merikangas KR, et al. The epidemiology of major depressive disorder: Results from the National Comorbidity Survey Replication (NCS–R). JAMA. 2003;289(23):3095-105. [pmid: 12813115].
3 World Health Organization. Depression. 2009. Available from: http://www.who.int/mental_health/management/depression/definition/en/.
4 Wells KB, Stewart A, Hays RD, Burnam MA, Rogers W, Daniels M, et al. The functioning and well-being of depressed patients: Results from the Medical Outcomes Study. JAMA. 1989;262(7):914-9. [pmid: 2754791].
5 Ebmeier KP, Donaghey C, Steele JD. Recent developments and current controversies in depression. Lancet. 2006;367(9505):153-67. [pmid: 16413879].
6 Keller MB. Past, present, and future directions for defining optimal treatment outcome in depression: Remission and beyond. JAMA. 2003;289(23):3152-60. [pmid: 12813121].
7 Wang PS, Lane M, Olfson M, Pincus HA, Wells KB, Kessler RC. Twelve-month use of mental health services in the United States: Results from the National Comorbidity Survey Replication. Arch Gen Psychiatry. 2005;62(6):629-40. [pmid: 15939840].
8 Kroenke K, Spitzer RL. The PHQ–9: A new depression diagnostic and severity measure. Psychiatr Ann. 2002;32(9):1-7.
9 Pratt LA, Brody DJ. Depression in the United States household population, 2005–2006. NCHS data brief, no 7. Hyattsville, MD. NCHS. 2008. Available from: http://www.cdc.gov/nchs/data/databriefs/db07.htm.
10 Lorant V, Deliège D, Eaton W, Robert A, Philippot P, Ansseau M. Socioeconomic inequalities in depression: A meta-analysis. Am J Epidemiol. 2003;157(2):98-112. [pmid: 12522017].
11 Miech RA, Shanahan MJ, Elder GH Jr. Socioeconomic status and depression in life course perspective, CDE Working Paper 98–24. Madison, WI. University of Wisconsin–Madison, Center for Demography and Ecology. 1998. Available from: http://www.ssc.wisc.edu/cde/cdewp/98-24.pdf.

## Edentulism (Lack of Natural Teeth)

The percentage of middle-age and older adults with edentulism (no natural teeth) increased with decreasing relative family income in 2000–2010.

Edentulism—the absence of any natural teeth—may occur for a variety of reasons but most commonly results from untreated dental caries or periodontal disease (1). Loss of teeth may also reflect poor dietary intake or limited access to oral health care (2). Edentulism is associated with morbidity, including heart disease and stroke (2). Over the past several decades, the prevalence of edentulism has declined, likely due to improved access to and use of oral health care services and fluoridated water, and lower prevalence of smoking among adults (1,3,4).

Edentulism increases with decreasing relative family income. In 2010, among adults 45–64 years of age, edentulism was 5 times as high for those living below poverty, 4.8 times as high for those at 100%–199% of the poverty level, and 2.7 times as high among those at 200%–399% of the poverty level, compared with those with income at 400% or more of the poverty level. In 2010, among adults 65 years of age and over, edentulism was 3 times as high for those living below poverty, 2.5 times as high for those at 100%–199% of the poverty level, and 1.8 times as high among those at 200%–399% of the poverty level, compared with those with income at 400% or more of the poverty level.

For both age groups, the percentage with edentulism has declined from 2000 to 2010. However, there has been a more rapid decline among adults in higher relative family income groups, resulting in an increase in the percent difference in edentulism between the lowest and highest groups over the past decade.

Figure 34 Edentulism (lack of natural teeth) among adults 45 years of age and over, by age and percent of poverty level: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig34

NOTE: See data table for Figure 34.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Figure 34 consists of two line graphs for age groups 45 to 64 years and 65 years and over, showing edentulism (lack of natural teeth), by percent of poverty level, for 2000 through 2010.

### References

1 U.S. Department of Health and Human Services. Oral health in America: A report of the Surgeon General. Rockville, MD. U.S. Department of Health and Human Services, National Institute of Dental and Craniofacial Research, National Institutes of Health. 2000. Available from: http://www.nidcr.nih.gov/DataStatistics/SurgeonGeneral/sgr/.
2 Holm-Pedersen P, Schultz-Larsen K, Christiansen N, Avlund K. Tooth loss and subsequent disability and mortality in old age. J Am Geriatr Soc. 2008;56(3):429-35. [pmid: 18194226].
3 Cunha-Cruz J, Hujoel PP, Nadanovsky P. Secular trends in socio-economic disparities in edentulism: USA, 1972–2001. J Dent Res. 2007;86(2):131-6. [pmid: 17251511].
4 CDC. Ten Great Public Health Achievements—United States 1900–1999. MMWR. 1999;48(12):241-3. Available from: http://www.cdc.gov/MMWR/preview/mmwrhtml/00056796.htm. [pmid: 10220250].

## Two or More Selected Chronic Health Conditions

The percentage of adults 45–64 years of age with two or more selected chronic health conditions increased with decreasing relative family income in 2009–2010.

Midlife is a time when the prevalence of chronic health conditions begins to increase (Tables 49–51). Studies suggest that the presence of more than one chronic condition adds a layer of complexity to disease management for the individual and the health care system, and increases health care utilization and expenditures (1–6).

Having two or more chronic conditions is defined as respondent-reported physician diagnosis of two or more of the following nine chronic conditions: heart disease, high blood pressure, stroke, emphysema, cancer, diabetes, current asthma, chronic bronchitis, or kidney disease (see data table for Figure 35 for exact survey questions and recall periods). Many of these conditions share a common set of modifiable risk factors that may vary by income. Cigarette smoking and lack of physical activity are more common for adults living in poverty than for those in higher relative family income groups (Tables 62 and 73, Figure 38). The prevalence of obesity and elevated cholesterol varies less by relative family income (Tables 71 and 74).

In both 1999–2000 and 2009–2010, the percentage of adults 45–64 years of age with two or more chronic conditions rose with decreasing relative family income. Between these two time periods, the prevalence of two or more chronic conditions increased more for those above poverty than below poverty, thereby narrowing the gap by relative family income; in 2009–2010, prevalence was twice as high among those with income below the poverty level compared with those with income at 400% or more of the poverty level.

Figure 35 Two or more selected chronic health conditions among adults 45–64 years of age, by percent of poverty level: United States, 1999–2000 and 2009–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#35

NOTES: Selected chronic conditions include ever told had heart disease, diabetes, cancer, hypertension (told at least twice), stroke, or emphysema; or told in last year had chronic bronchitis or kidney disease; or reported having an asthma attack in past year. See data table for Figure 35.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Figure 35 is a bar chart showing two or more selected chronic conditions among adults 45 to 64 years of age, by percent of poverty level, for 1999 through 2000 and 2009 through 2010.

### References

1 Benjamin RM. Multiple chronic conditions: A public health challenge. Surgeon General’s Perspectives. Public Health Rep. 2010;125:626-7. [pmid: 20873276].
2 U.S. Department of Health and Human Services. HHS initiative on multiple chronic conditions. 2011. Available from: http://www.hhs.gov/ash/initiatives/mcc/.
3 Anderson G. Chronic care: Making the case for ongoing care. Princeton, NJ. Robert Wood Johnson Foundation. 2010. Available from: http://www.rwjf.org/files/research/50968chronic.care.chartbook.pdf.
4 Wolff JL, Starfield B, Anderson G. Prevalence, expenditures, and complications of multiple chronic conditions in the elderly. Arch Intern Med. 2002;162(20):2269-76. [pmid: 12418941].
5 Paez KA, Zhao L, Hwang W. Rising out-of-pocket spending for chronic conditions: A ten-year trend. Health Aff (Millwood). 2009;28(1):15-25. [pmid: 19124848].
6 Vogeli C, Shields AE, Lee TA, Gibson TB, Marder WD, Weiss KB, Blumenthal D. Multiple chronic conditions: Prevalence, health consequences, and implications for quality, care management, and costs. J Gen Intern Med. 2007;22(suppl 3):391-5. [pmid: 18026807].