# Introduction

Socioeconomic status (SES) is a multidimensional concept comprising measures of resources such as income, wealth, and educational credentials, and the access to goods, services, and knowledge that these resources afford those who have them. SES is a measure that allows comparisons between individuals, households, and groups (1,2). It is most commonly measured using educational attainment, income or poverty status, and, when available, wealth, employment, and occupational status.

This chartbook examines how health varies across four categories of each of two SES measures. Educational attainment is categorized as less than high school diploma, high school graduate or GED, some college, and Bachelor’s degree or higher. Relative family income, defined as family income as a percentage of the applicable poverty threshold, is categorized as below the poverty level, 100%–199% of the poverty level, 200%–399% of the poverty level, and 400% or more of the poverty level.

In the United States, SES varies markedly by race and ethnicity. Asian persons and white persons are disproportionately represented among the higher SES groups, and black and Hispanic persons are disproportionately represented among the lower SES groups (Figures 22 and 31). In addition, the relationship between SES and health may differ within race and ethnicity groups. Therefore, when health outcomes are presented by SES groups it is often useful to stratify by race and ethnicity to help interpret patterns and differences. In this chartbook, many of the figures that show the relationship between SES and health measures also display that relationship within race and ethnicity groups.

The association between SES measures, such as education and income, and health is well established, but the mechanisms are less clear. The link between education and health appears to operate through several pathways. Highly educated persons are more likely to be employed and well-paid than the less educated. They have a higher sense of control over their health and lives and more social support (3). In addition, the well-educated are more likely to engage in healthy behaviors and avoid unhealthy ones (3). All of these factors are associated with better health (4) and help explain health differences by education level. In addition to the effects of high SES on health, poor health may limit the ability to work or function in society and can lead to lower income and more difficulty obtaining educational and employment opportunities (5).

Health-related behaviors such as cigarette smoking and physical inactivity are more common among those with lower SES than among their high-SES peers (Tables 62 and 73, Figure 38) (6,7). Living and working environments also affect health and vary by SES. Low-SES children and adults tend to live in low-income, low-resource neighborhoods, which are negatively associated with various health outcomes (8–11).

SES also affects health through its association with the ability to access health care, including preventive services, screenings, and medical treatments. Health insurance facilitates access to the health care system; people without insurance are less likely to receive needed health care (6,12). Nonelderly adults with family income below 400% of the poverty level are more likely to be uninsured than those in the highest relative family income group (Figure 40). Similarly, adults without a high school education are four times as likely to lack health insurance as those with a Bachelor’s degree (6). These disparities in insurance contribute to SES health disparities and help to explain why low-income and less educated people have less access to care than higher income and more educated persons.

Preventive health services such as immunizations prevent infectious diseases, and screening and early detection of diseases such as cancer can substantially increase longevity and quality of life. SES disparities in receipt of such services start early in life and continue through old age. Low-SES women are less likely to use contraception at first sexual intercourse than high-SES women (13). Less educated and lower income pregnant women are less likely to receive adequate prenatal care (14). The percentage of children who receive recommended vaccinations rises with maternal education and income, although these gaps have narrowed in the 2000s (15,16). SES disparities persist into adulthood. Those with higher education and income are more likely to undergo mammography and colorectal cancer tests and procedures (Tables 90 and 92, Figure 39) (6,17). Elderly adults without a high school diploma are less likely than their more educated peers to receive an influenza or pneumococcal vaccination (Tables 88 and 89).

Because health varies by SES, it is important to track changes in health within SES groups over time to examine how disparities change over time. Changes in overall health may be due to changes in the health of either low- or higher SES persons or some combination of both. Greater engagement in high-risk behaviors, greater exposure to unhealthy environments, and less access to care and services by lower income and less educated populations can lead to worse health, greater disease burdens, higher death rates, and shorter lives than for the higher income and more educated (18–20). From the early 1980s to 2000, the gap in life expectancy between those in the lowest and highest SES groups widened because life expectancy increased more for high-SES individuals (21). More recently, the gap in life expectancy between the least and most educated has continued to grow for both men and women (Figure 32).

Some success in narrowing, albeit not eliminating, health gaps has occurred for children. Between 2000 and 2010, the percentage of uninsured children living below 200% of the poverty level dropped by about one-half (Figure 29). The introduction and expansion of the Children’s Health Insurance Program (CHIP) is largely responsible for narrowing the coverage gap among children (22,23). Yet low income children remain five times as likely to be uninsured as those at 400% or more of the poverty level (Figure 29, Table 141).

The reduction in elevated blood lead levels, and the elimination of the disparity in elevated lead levels by SES, represent additional success in reducing health gaps. Laws banning lead from various sources, such as gasoline and paint, led to a drop in the concentration of lead found in children’s blood. Moreover, the inverse relationship between SES and blood lead concentration found several decades ago has virtually disappeared. Poor children have blood lead concentrations no greater, on average, than affluent children (24).

Although there have been improvements in many health indicators over time for adults at all SES levels, this chartbook shows that gaps in health indicators between low- and high-SES individuals remain. Obesity, which raises the risk for conditions such as diabetes, heart disease, and some types of cancer, is more common in adults without a college degree than in those who have finished college (Figure 37). Similarly, depression (Figure 33), edentulism (Figure 34), functional limitations (Figure 36), cigarette smoking (Figure 38), lacking health insurance (Figure 40), and having unmet need for medical care due to cost (Figure 41) are all more common for adults at lower than higher SES.

This Special Feature focuses on the relationship between SES and health using a four-category education variable and a four-category relative family income variable as SES measures. Charts on trends in poverty and differences in relative family income by race and Hispanic origin for children and adults are presented to provide context for the other charts. This Feature explores the SES gradient in health measures for children and adults and how that gradient differs across racial and ethnic groups. When possible, trend data are presented to examine changes in SES disparities over time. Charts present information on associations between SES and morbidity and mortality, prevention and risk factors, and access to care and health insurance. Together, they provide a broad picture of the relationship between Americans’ SES and their health.

## References

1 Krieger N, Williams DR, Moss NE. Measuring social class in U.S. public health research: Concepts, methodologies, and guidelines. Annu Rev Public Health. 1997;18:341-78. [pmid: 9143723].
2 Liberatos P, Link BG, Kelsey JL. The measurement of social class in epidemiology. Epidemiol Rev. 1988;10:87-121. [pmid: 3066632].
3 Ross CE, Wu C. The links between education and health. Am Sociol Rev. 1995;60(5):719-45.
4 Cohen S. Social relationships and health. Am Psychol. 2004;59(8):676-84. [pmid: 15554821].
5 Smith JP. Unraveling the SES–health connection. Popul Dev Rev. 2004;30:108-32.
6 CDC. CDC health disparities and inequalities report: United States, 2011. MMWR. 2011;60(suppl). Available from: http://www.cdc.gov/mmwr/pdf/other/su6001.pdf.
7 Winkleby MA, Jatulis DE, Frank E, Fortmann SP. Socioeconomic status and health: How education, income, and occupation contribute to risk factors for cardiovascular disease. Am J Public Health. 1992;82(6):816-20. [pmid: 1585961].
8 Casagrande SS, Whitt-Glover MC, Lancaster KJ, Odoms-Young AM, Gary TL. Built environment and health behaviors among African Americans: A systematic review. Am J Prev Med. 2009;36(2):174-81. [pmid: 19135908].
9 Gordon-Larsen P, Nelson MC, Page P, Popkin BM. Inequality in the built environment underlies key health disparities in physical activity and obesity. Pediatrics. 2006;117(2):417-24. [pmid: 16452361].
10 Ross CE, Mirowsky J. Neighborhood disadvantage, disorder, and health. J Health Soc Behav. 2001;42(3):258-76. [pmid: 11668773].
11 Wight RG, Cummings JR, Miller-Martinez D, Karlamangla AS, Seeman TE, Aneshensel CS. A multilevel analysis of urban neighborhood socioeconomic disadvantage and health in late life. Soc Sci Med. 2008;66(4):862-72. [pmid: 18160194].
12 Agency for Healthcare Research and Quality. 2010 National Healthcare Disparities Report. AHRQ pub no 11–0005. Rockville, MD. AHRQ. 2011. Available from: http://www.ahrq.gov/qual/nhdr10/nhdr10.pdf.
13 Mosher WD, Jones J. Use of contraception in the United States: 1982–2008, NCHS. Vital Health Stat. 2010;23(29). Available from: http://www.cdc.gov/NCHS/data/series/sr_23/sr23_029.pdf.
14 Frisbie WP, Echevarria S, Hummer RA. Prenatal care utilization among non-Hispanic whites, African Americans, and Mexican Americans. Matern Child Health J. 2001;5(1):21-33. [pmid: 11341717].
15 Wooten KG, Luman ET, Barker LE. Socioeconomic factors and persistent racial disparities in childhood vaccination. Am J Health Behav. 2007;31(4):434-45. [pmid: 17511578].
16 Zhao Z, Luman ET. Progress toward eliminating disparities in vaccination coverage among U.S. children, 2000–2008. Am J Prev Med. 2010;38(2):127-37. [pmid: 20117568].
17 Kim J, Jang SN. Socioeconomic disparities in breast cancer screening among U.S. women: Trends from 2000 to 2005. J Prev Med Public Health. 2008;41(3):186-94. [pmid: 18515996].
18 Krueger PM, Chang VW. Being poor and coping with stress: Health behaviors and the risk of death. Am J Public Health. 2008;98(5):889-96. [pmid: 18382003].
19 Winkleby MA, Cubbin C. Influence of individual and neighborhood socioeconomic status on mortality among black, Mexican-American, and white women and men in the United States. J Epidemiol Community Health. 2003;57(6):444-52. [pmid: 12775792].
20 Kaplan GA, Keil JE. Socioeconomic factors and cardiovascular disease: A review of the literature. Circulation. 1993;88(4 pt 1):1973-98. [pmid: 8403348].
21 Singh GK, Siahpush M. Widening socioeconomic inequalities in U.S. life expectancy, 1980–2000. Int J Epidemiol. 2006;35(4):969-79. [pmid: 16684899].
22 Dubay L, Kenney G. The impact of CHIP on children’s insurance coverage: An analysis using the National Survey of America’s Families. Health Serv Res. 2009;44(6):2040-59. [pmid: 19780856].
23 Hudson JL, Sleden TM, Banthin JS. The impact of SCHIP on insurance coverage of children. Inquiry. 2005;42(3):232-54. [pmid: 16353761].
24 CDC/NCHS. National Health and Nutrition Examination Survey. [unpublished analysis].