# Health Risk Factors

## Adult Obesity

In 2007–2010, obesity prevalence for women was higher among those with less than a Bachelor’s degree, compared with women with more education; obesity among men did not have a clear relationship to educational attainment.

Obesity (body mass index of 30.0 or higher) is associated with excess mortality and morbidity (1–3). Obesity is also associated with increased risk of heart disease, stroke, some cancers, diabetes, osteoarthritis, and disability (1,2,4). Diet, physical inactivity, genetic factors, environment, and health conditions contribute to obesity. Previous research has found that the prevalence of obesity is significantly lower among those with college degrees compared with those with some college (5).

In both 1988–1994 and 2007–2010, obesity was higher among women with less than a Bachelor’s degree compared with those with higher educational attainment. In 2007–2010, two-fifths (39%–43%) of women in the lower educational attainment groups were obese, compared with one-quarter of women with a Bachelor’s degree or higher education. The relationship between educational attainment and obesity levels was less clear among men.

Obesity prevalence increased for men and women 25 years of age and over at all education levels from 1988–1994 through 2007–2010. Over the period, the percentage increase in obesity prevalence was largest for men with at least some college and for women with at least some college or a Bachelor’s degree or higher education, resulting in a narrowing of the gap in obesity by education. In 1988–1994, the overall obesity rate for women was higher than for men; by 2007–2010, obesity rates were similar for men and women.

Figure 37 Obesity among adults 25 years of age and over, by sex and education level: United States, 1988–1994 and 2007–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig37

NOTES: GED is General Educational Development high school equivalency diploma. See data table for Figure 37.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey. See Appendix I, National Health and Nutrition Examination Survey (NHANES).

Figure 37 consists of two bar charts, one for men and one for women, showing obesity among adults 25 years of age and over, by education level, for 1988 through 1994 and 2007 through 2010.

### References

1 National Heart, Lung, and Blood Institute and National Institute of Diabetes and Digestive and Kidney Diseases. Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults: The evidence report. NIH pub no 98–4083. Bethesda, MD. National Institutes of Health. 1998. Available from: http://www.nhlbi.nih.gov/guidelines/obesity/ob_gdlns.pdf.
2 National Institute of Diabetes and Digestive and Kidney Diseases. Overweight, obesity, and health risk: National Task Force on the Prevention and Treatment of Obesity. Arch Intern Med. 2000;160(7):898-904. [pmid: 10761953].
3 Flegal KM, Graubard BI, Williamson DF, Gail MH. Excess deaths associated with underweight, overweight, and obesity. JAMA. 2005;293(15):1861-7. [pmid: 15840860].
4 Gregg EW, Guralnik JM. Is disability obesity’s price of longevity?. JAMA. 2007;298(17):2066-7. [pmid: 17986703].
5 Ogden CL, Lamb MM, Carroll MD, Flegal KM. Obesity and socioeconomic status in adults: United States, 2005–2008. NCHS data brief, no 50. Hyattsville, MD. NCHS. 2010. Available from: http://www.cdc.gov/nchs/data/databriefs/db50.htm.

## Current Cigarette Smoking

Cigarette smoking prevalence is higher among adults with less educational attainment; this negative relationship between education and smoking is stronger among adults 25–64 years of age than among adults 65 years of age and over.

Tobacco use, primarily cigarette smoking, continues to be the leading cause of preventable disease, disability, and death in the United States (1,2). Each year, an estimated 443,000 premature deaths are caused from smoking or exposure to secondhand smoke (1). In 2010, 19% of adults 25 years of age and over were current cigarette smokers (data table for Figure 38).

In 2010, the prevalence of current smoking was 3.4 times as high among adults 25–64 years of age with a high school diploma or less education, and 2.6 times as high for those with some college, compared with those with a Bachelor’s degree or higher. Among adults 65 years of age and over, smoking prevalence was more than double among those with less than a high school diploma, 1.7 times higher among those with a high school degree, and double among those with some college, compared with those with a Bachelor’s degree or higher education.

During 2000–2010, the percentage of current smokers among adults 25–64 years of age declined for those without a high school diploma and for those with a Bachelor’s degree or higher education. The decline was greater among those with a Bachelor’s degree or higher, widening the relative gap in smoking prevalence between the lowest and highest education groups. In the past decade, there has been no change in smoking prevalence among adults 65 years of age and over, regardless of education level.

Figure 38 Current cigarette smoking among adults 25 years of age and over, by age and education level: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig38

NOTES: GED is General Educational Development high school equivalency diploma. See data table for Figure 38.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Figure 38 consists of two line graphs, one for adults 25 to 64 years of age and one for adults 65 years of age and over, showing current cigarette smoking, by education level, for 2000 through 2010.

### References

1 National Center for Chronic Disease Prevention and Health Promotion. Tobacco use: Targeting the Nation’s leading killer—At a glance 2011. 2011. Available from: http://www.cdc.gov/chronicdisease/resources/publications/aag/pdf/2011/Tobacco_AAG_2011_508.pdf.
2 CDC. Vital Signs: Current cigarette smoking among adults aged ≥18 years—United States, 2005–2010. MMWR. 2011;60(35):1207-12. Available from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm6035a5.htm?s_cid=mm6035a5_w. [pmid: 21900875].