# Health Risk Factors

## Child Obesity

In 2007–2010, the prevalence of obesity was higher among boys and girls whose household head had lower educational attainment.

Excess body weight in children is associated with excess morbidity in childhood and adulthood (1). Obesity among children and teenagers 2–19 years of age is defined as a body mass index (BMI) for age and sex at or above the 95th percentile of the CDC growth charts (2,3). SES has generally been found to be inversely associated with obesity in children and adolescents (4–9), but this association may vary by race (10).

In 2007–2010, obesity for boys was double for those whose household head had less than a high school education, and about 60% higher for those whose household head had a high school degree or some college, compared with those whose household head had a Bachelor’s degree or higher education. Among girls, obesity was about three times as high for those whose household head had a high school degree or less education, and about twice as high for those whose household head had some college, compared with those whose household head had a Bachelor’s degree or higher.

Between 1988–1994 and 2007–2010, the percentage of boys and girls who were obese increased within each household head education level except those with a Bachelor’s degree or higher, resulting in a widening of the gap in child obesity between children at the lowest and highest SES levels. In 2007–2010, 18% of boys and 15% of girls were obese.

Figure 25 Obesity among children 2–19 years of age, by sex of child and education level of head of household: United States, 1988–1994 and 2007–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig25

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error (RSE) of 20%–30%. Data not shown have an RSE of greater than 30%.

NOTES: GED is General Educational Development high school equivalency diploma. Education level is for head of household. Obesity is body mass index at or above the sex- and age-specific 95th percentile from the 2000 CDC Growth Charts. See data table for Figure 25.

SOURCE: CDC/NCHS, National Health and Nutrition Examination Survey. See Appendix I, National Health and Nutrition Examination Survey (NHANES).

Figure 25 consists of two bar charts, one for boys and one for girls, showing obesity among children 2 to 19 years of age, by education level of household head, for 1988 through 1994 and 2007 through 2010.

### References

1 Dietz WH. Health consequences of obesity in youth: Childhood predictors of adult disease. Pediatrics. 1998;101(3 pt 2):518-25. [pmid: 12224658].
2 Kuczmarski RJ, Ogden CL, Guo SS, et al. CDC Growth Charts for the United States: Methods and development. NCHS. Vital Health Stat. 2000;11(246):2002. Available from http://www.cdc.gov/nchs/data/series/sr_11/sr11_246.pdf.
3 Ogden CL, Flegal KM. Changes in terminology for childhood overweight and obesity. National health statistics reports; no 25. Hyattsville, MD. NCHS. 2010. Available from: http://www.cdc.gov/nchs/data/nhsr/nhsr025.pdf.
4 Delva J, O’Malley PM, Johnston LD. Racial/ethnic and socioeconomic status differences in overweight and health-related behaviors among American students: National trends 1986–2003. J Adolesc Health. 2006;39(4):536-45. [pmid: 16982389].
5 Goodman E. The role of socioeconomic status gradients in explaining differences in U.S. adolescents’ health. Am J Public Health. 1999;89(10):1522-8. [pmid: 10511834].
6 Haas JS, Lee LB, Kaplan CP, Sonneborn D, Phillips KA, Liang SY. The association of race, socioeconomic status, and health insurance status with the prevalence of overweight among children and adolescents. Am J Public Health. 2003;93(12):2105-10. [pmid: 14652342].
7 Singh GK, Siahpush M, Kogan MD. Rising social inequalities in U.S. childhood obesity, 2003–2007. Ann Epidemiol. 2010;20(1):40-52. [pmid: 20006275].
8 Wang Y, Zhang Q. Are American children and adolescents of low socioeconomic status at increased risk of obesity? Changes in the association between overweight and family income between 1971 and 2002. Am J Clin Nutr. 2006;84(4):707-16. [pmid: 17023695].
9 Ogden CL, Lamb MM, Carroll MD, Flegal KM. Obesity and socioeconomic status in children and adolescents: United States, 2005–2008. NCHS data brief no 51. Hyattsville, MD. NCHS. 2010. Available from: http://www.cdc.gov/nchs/data/databriefs/db51.pdf.
10 Zhang Q, Wang Y. Using concentration index to study changes in socio-economic inequality of overweight among U.S. adolescents between 1971 and 2002. Int J Epidemiol. 2007;36(4):916-25. [pmid: 17470489].

## Children’s Screen Time

Children with family income below 400% of poverty were more likely to engage in more than 2 hours of screen time daily than children at 400% or more of the poverty level.

Sedentary behavior, such as watching television and playing video games, has been cited as contributing to rising obesity rates among children. Some research (1–5) has found positive associations between television viewing and higher body mass index or obesity. Other research (6) suggests that video games, but not television, are associated with youth obesity. Still other work (7) found an association between obesity and commercial, but not noncommercial, television. The American Academy of Pediatrics recommends that children engage in less than 2 hours of screen time daily (8).

Children 6–11 years of age in families below 400% of poverty were more likely to spend more than 2 hours on an average weekday watching television and videos, playing video games, or on a computer (screen time) than children in the highest relative family income group. Screen time excludes computer use for homework. On average during 2003 and 2007, about 4 in 10 (38%–43%) children in families up to 400% of poverty spent more than 2 hours per day in front of a screen compared with 3 in 10 (31%) children living at 400% or more of the poverty level. This pattern was similar for boys and girls.

Figure 26 Children 6–11 years of age who engaged in more than 2 hours of screen time daily, by sex and percent of poverty level: United States, average annual, 2003 and 2007

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig26

NOTES: Screen time includes watching TV or videos, playing video games, or non-school-related computer use. See data table for Figure 26.

SOURCE: CDC/NCHS, National Survey of Children’s Health. See Appendix I, National Survey of Children’s Health (NSCH).

Figure 26 is a bar chart showing children 6 to 11 years of age who engaged in more than 2 hours of screen time daily, by sex and percent of poverty level, for 2003 and 2007.

### References

1 Andersen RE, Crespo CJ, Bartlett SJ, Cheskin LJ, Pratt M. Relationship of physical activity and television watching with body weight and level of fatness among children: Results from the third National Health and Nutrition Examination Survey. JAMA. 1998;279(12):938-42. [pmid: 9544768].
2 Crespo CJ, Smit E, Troiano RP, Bartlett SJ, Macera CA, Andersen RE. Television watching, energy intake, and obesity in U.S. children: Results from the third National Health and Nutrition Examination Survey, 1988–1994. Arch Pediatr Adolesc Med. 2001;155(3):360-5. [pmid: 11231802].
3 Danner FW. A national longitudinal study of the association between hours of TV viewing and the trajectory of BMI growth among U.S. children. J Pediatr Psychol. 2008;33(10):1100-7. [pmid: 18390579].
4 Giammattei J, Blix G, Marshak HH, Wollitzer AO, Pettitt DJ. Television watching and soft drink consumption: Associations with obesity in 11- to 13-year-old schoolchildren. Arch Pediatr Adolesc Med. 2003;157(9):882-6. [pmid: 12963593].
5 Gortmaker SL, Must A, Sobol AM, Peterson K, Colditz GA, Dietz WH. Television viewing as a cause of increasing obesity among children in the United States, 1986–1990. Arch Pediatr Adolesc Med. 1996;150(4):356-62. [pmid: 8634729].
6 Vandewater EA, Shim MS, Caplovitz AG. Linking obesity and activity level with children’s television and video game use. J Adolesc. 2004;27(1):71-85. [pmid: 15013261].
7 Zimmerman FJ, Bell JF. Associations of television content type and obesity in children. Am J Public Health. 2010;100(2):334-40. [pmid: 20019313].
8 American Academy of Pediatrics, Committee on Communications and Media. Policy statement—Media violence. Pediatrics. 2009;124(5):1495-503. [pmid: 19841118].