# Health Insurance

## Uninsured Adults

Adults 18–64 years of age who were living below 200% of the poverty level were more likely to be uninsured than those with higher relative family income in 2000–2010.

In 2010, 42.5 million adults 18–64 years of age had no health insurance coverage (1). Since 1999, employer-sponsored coverage has decreased and the number of uninsured adults 18–64 years of age has increased (Tables 139 and 141). Adults with family income below 200% of the poverty level are more likely to be uninsured and are less likely to receive insurance through the workplace than those with higher family income (Tables 139 and 141) (2). Uninsured adults are more likely to delay or forego needed care and are less likely to seek preventive care than the insured (Table 79) (2). This may lead to serious health problems and greater medical expenses in the future.

Between 2000 and 2010, the percentage of uninsured adults 18–64 years of age increased by 6 percentage points for those at 100%–199% of the poverty level and 3 percentage points for those at 200%–399% of the poverty level, while remaining stable for those living below poverty and at 400% or more of the poverty level. Throughout this decade, adults living at less than 200% of the poverty level were five to seven times as likely, and those living at 200%–399% of the poverty level were about three times as likely, to be uninsured, compared with adults living at 400% or more of the poverty level (data table for Figure 40).

In 2009–2010, within each racial and ethnic group, adults living below 200% of poverty were more likely to be uninsured than those with higher income. Within each relative income group, the percent uninsured was higher for Hispanic adults than for those in any other race or ethnicity group.

Figure 40 No health insurance coverage among adults 18–64 years of age, by percent of poverty level and race and Hispanic origin: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig40

NOTE: See data table for Figure 40.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Figure 40 consists of a line graph and a bar chart showing no health insurance coverage among adults 18 to 64 years of age, by percent of poverty level and race and Hispanic origin, for 2000 through 2010.

## References

1 Cohen RA, Ward BW, Schiller JS. Health insurance coverage: Early release of estimates from the National Health Interview Survey, 2010. NCHS. June. 2011. Available from: http://www.cdc.gov/nchs/data/nhis/earlyrelease/insur201106.htm.
2 Kaiser Commission on Medicaid and the Uninsured. The uninsured and the difference health insurance makes. 2010. Available from: http://www.kff.org/uninsured/upload/1420-12.pdf.