# Health Insurance

## Uninsured Children

Between 2000 and 2010, gains in insurance coverage for children in families below 200% of the poverty level resulted in a narrowing of the gap in the percentage of children who were uninsured across relative family income groups.

Children need access to the health care system for diagnosis and treatment of acute and chronic illnesses, treatment of injuries, and preventive care. Health insurance is a major determinant of access to care; in 2010, there were 5.8 million uninsured children under 18 years of age (1). Children are less likely to be uninsured than adults 18–64 years of age because they are more likely to qualify for public coverage, primarily Medicaid (2). The Children’s Health Insurance Program (CHIP) provides coverage to eligible low-income, uninsured children who do not qualify for Medicaid (3).

During 2000–2010, the percentage of children living below 200% of poverty who were uninsured was cut almost in half, while the percentage who were uninsured in higher relative family income groups declined at a slower rate, narrowing the gap in uninsurance by relative family income. Throughout this period, children below 200% of poverty were the most likely to be uninsured. By 2010, compared with children with family income at 400% or more of the poverty level, those below 200% of the poverty level were five to six times as likely, and those at 200%– 399% were three times as likely, to be uninsured.

In 2009–2010, for Hispanic and non-Hispanic black children below 200% of poverty, uninsurance percentages were two to three times higher than for those in families at 400% or more of poverty. For non-Hispanic white children, percentages were three to six times higher among lower family income groups.

Figure 29 No health insurance coverage among children under 18 years of age, by percent of poverty level and race and Hispanic origin: United States, 2000–2010

Excel and PowerPoint: http://www.cdc.gov/nchs/hus/contents2011.htm#fig29

* Estimates are considered unreliable. Data preceded by an asterisk have a relative standard error (RSE) of 20%–30%. Data not shown have an RSE of greater than 30%.

NOTE: See data table for Figure 29.

SOURCE: CDC/NCHS, National Health Interview Survey. See Appendix I, National Health Interview Survey (NHIS).

Figure 29 consists of a line graph and a bar chart showing no health insurance coverage among children under 18 years of age, by percent of poverty level and race and Hispanic origin, for 2000 through 2010.

## References

1 Cohen RA, Ward BW, Schiller JS. Health insurance coverage: Early release of estimates from the National Health Interview Survey, 2010. NCHS. June. 2011. Available from: http://www.cdc.gov/nchs/data/nhis/earlyrelease/insur201106.htm.
2 Kaiser Commission on Medicaid and the Uninsured. The uninsured and the difference health insurance makes. 2010. Available from: http://www.kff.org/uninsured/upload/1420-12.pdf.
3 Centers for Medicare & Medicaid Services. Children’s Health Insurance Program (CHIP). Available from: http://www.cms.hhs.gov/NationalCHIPPolicy/.